# Cultural Competency and Diversity Network Participants

- Charles H. Bombardier, Ph.D.
  Associate Professor
  Department of Rehabilitation Medicine
  Harborview Medical Center
  University of Washington School of Medicine
  Seattle, WA
  Disability Workgroup
- Carol S. D’Agostino, CSW, CASAC
  Director
  Geriatric Addictions Program
  LIFESPAN of Greater Rochester, Inc.
  Rochester, NY
  Aging Workgroup
- Thomas L. Geraty, M.S.W., Ph.D., LICSW
  Private Practice
  Jamaica Plain, MA
  LGBT Workgroup
- Wayne Lee Mitchell, M.D.
  Indian Health Service
  Phoenix, AZ
  Aging Workgroup
- Ann S. Yabusaki, M.Ed., M.A., Ph.D.
  Substance Abuse Director
  Psychologist
  Substance Abuse Programs and Training
  Coalition for a Drug-Free Hawaii
  Kaneohe, HI
  Asian and Pacific Islanders Workgroup and Aging Workgroup