# Field Reviewers

- Carol Ackley
  Owner/Director
  River Ridge Treatment Center
  Burnsville, MN
- Rosie Anderson-Harper, M.A.
  Mental Health Manager
  Division of Alcohol and Drug Abuse
  Missouri Department of Mental Health
  Jefferson City, MO
- Reba Architzel
  Director
  Federal Relations and Policy Analysis
  New York State Office of Alcoholism and Substance Abuse Services
  Albany, NY
- Larry L. Ashley, Ed.S., M.A.
  Addictions Specialist
  Department of Counseling
  University of Nevada, Las Vegas
  Las Vegas, NV
- G.T. (Gigi) Belanger
  Public Health Advisor
  Homeless Programs Branch
  Center for Mental Health Services
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Charles H. Bombardier, Ph.D.
  Associate Professor
  Department of Rehabilitation Medicine
  Harborview Medical Center
  University of Washington School of Medicine
  Seattle, WA
- Patricia T. Bowman
  Probation Counselor
  Fairfax Alcohol Safety Action Program
  Fairfax, VA
- Patricia Allen Bradford, LISW, LMFT, CTS
  Program Manager
  Health Care for Homeless Veterans
  Columbia, SC
- Kathy Brock
  Director
  Polytechnic University Counseling Center
  Brooklyn, NY
- Vivian B. Brown, Ph.D.
  Chief Executive Officer
  Mental Health and Social Services Centers for Innovation in Health
  PROTOTYPES
  Culver City, CA
- Wilma J. Calvert, R.N., Ph.D.
  Post-Doctoral Fellow
  Department of Psychiatry
  Washington University School of Medicine
  St. Louis, MO
- Jerome F.X. Carroll, Ph.D.
  Consultant in private practice
  Chair, Columbia University’s Drugs & Society Seminar
  Brooklyn, NY
- Steven J. Chen, Ph.D.
  Associate Director
  Division of Substance Abuse and Mental Health
  Utah Department of Human Services
  Salt Lake City, UT
- Colleen Clark, M.A., Ph.D.
  Research Assistant Professor
  Licensed Clinical Psychologist
  Triad Women’s Project
  University of South Florida
  Tampa, FL
- R.T. Codd, III., Ed.S.
  Certified Member of the Academy of Cognitive Therapy
  Director/Owner
  Cognitive–Behavioral Therapy Center of Western North Carolina
  Asheville, NC
- Carol Coley, M.S.
  Senior Program Management Advisor
  Division of State and Community Assistance
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Carol J. Colleran, CAP, ICADC
  Director of Primary Programs
  Center of Recovery for Older Adults
  Hanley-Hazelden Center
  West Palm Beach, FL
- Stephanie S. Covington, M.S.W., Ph.D.
  Co-Director
  Center for Gender and Justice
  Institute for Relational Development
  La Jolla, CA
- David A. Deitch, Ph.D.
  Professor of Clinical Psychiatry
  Director, CCARTA
  Department of Clinical Psychiatry
  University of California, San Diego
  La Jolla, CA
- Gail D. Dixon, M.A., CAPP
  NIDA Project Manager
  Southern Coast Addiction Technology Transfer Center
  Tallahassee, FL
- Jill Shepard Erickson, M.S.W., ACSW
  Public Health Advisor
  Child and Family Branch
  Center for Mental Health Services
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Phil Erickson
  Substance Abuse Program Manager
  Loudoun County Community Services Board
  Leesburg, VA
- Kathleen J. Farkas, Ph.D., LISW
  Mandel School of Applied Social Sciences
  Case Western Reserve University
  Cleveland, OH
- Norma B. Finkelstein, M.S.W., Ph.D.
  Executive Director
  W.E.L.L. Project
  Institute for Health and Recovery
  Cambridge, MA
- Jerry P. Flanzer, D.S.W., LCSW, CAC
  Chief
  Services Research Branch
  National Institute on Drug Abuse
  National Institutes of Health
  Bethesda, MD
- Judith Ford, M.A., MFT
  Director of Women’s Services
  Community Services and Hospitals
  Connecticut Department of Mental Health and Addiction Services
  Hartford, CT
- Julian D. Ford, Ph.D.
  Associate Professor
  Department of Psychiatry
  University of Connecticut Health Center
  Farmington, CT
- Matthew Friedman, M.D., Ph.D.
  Professor of Psychiatry and Pharmacology
  Executive Director, National Center for PTSD
  Dartmouth Medical School
  VA Medical Center
  White River Junction, VT
- John Galea, M.A.
  Deputy Director, New York City Relations
  New York State Office of Alcoholism and Substance Abuse Services
  New York, NY
- Angela M. Gonzalez, Ph.D., CAPT., USPHS
  Scientist Officer
  Special Programs Development Branch-Refugee Mental Health Program
  Division of Prevention, Traumatic Stress, and Special Programs
  Center for Mental Health Services
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Maya D. Hennessey
  Women’s Specialist
  Supervisor, Quality Assurance, Technical Assistance & Training
  Office of Special Programs
  Division of Substance Abuse
  Illinois Department of Human Services and Substance Abuse
  Chicago, IL
- Michael W. Herring, LCSW
  Licensed Clinical Social Worker
  Wayne Psychiatric Associates, P.A.
  Goldsboro, NC
- Nancy J. Hirzel
  Clinic Director
  Adult Services Division
  Jefferson Addictive Disorders Clinic
  Jefferson Parish Human Services Authority
  Metairie, LA
- Robert Holden, M.A.
  Program Director
  Partners in Drug Abuse Rehabilitation Counseling (PIDARC)
  Washington, DC
- Kay M. Johnson
  Crime Victims Treatment Center - HIV Project
  St. Luke’s Roosevelt Hospital Center
  New York, NY
- Kimberly A. Johnson, M.A., NCAC II
  Director
  Augusta Mental Health Complex
  Maine Office of Substance Abuse
  Augusta, ME
- Sharon D. Johnson, M.S.W., M.P.E., Ph.D.
  Assistant Professor
  Department of Social Work
  University of Missouri-St. Louis
  St. Louis, MO
- Lorene Lake, M.A., Ed.D.
  Executive Director
  Chrysalis House, Inc.
  Crownsville, MD
- Michael S. Levy, Ph.D.
  Director of Clinical Treatment Services
  CAB Health and Recovery Services
  Danvers, MA
- T.K. Logan, Ph.D.
  Associate Professor
  Center on Drug & Alcohol Research
  Department of Behavioral Science
  University of Kentucky
  Lexington, KY
- James J. Manlandro, D.O., FAOAAM, FACOFP
  Medical Director
  Family Addiction Treatment Services, Inc.
  Somers Point, NJ
- Rozanne Marel, Ph.D.
  Head of Epidemiology & Needs Assessment
  New York State Office of Alcoholism and Substance Abuse Services
  New York, NY
- Pamela Martin, Ph.D.
  Director
  Behavioral Health Services Division
  New Mexico Department of Health
  Santa Fe, NM
- Ruby J. Martinez, Ph.D., R.N., CS
  Assistant Professor
  School of Nursing
  University of Colorado Health Sciences Center
  Denver, CO
- Sue Martone, M.P.A.
  Public Health Advisor
  Office of Disease Prevention and Health Promotion
  U.S. Department of Health and Human Services
  Washington, DC
- Beth Marty, M.S., LPC
  Clinical Program Manager
  WYSTAR
  Sheridan, WY
- Lisa A. Melchior, Ph.D.
  Vice President
  The Measurement Group, LLC
  Culver City, CA
- Candace Merritt
  Social Worker
  Veterans Administration Medical Center
  Denver, CO
- Pamela A. Mumby, C.N.S., F.N.P., M.S.N.
  Adult Psychiatric Nurse Practitioner
  Substance Abuse Treatment Program
  Veterans Administration Medical Center
  Denver, CO
- Briana S. Nelson-Goff, Ph.D.
  Associate Professor
  Family Studies and Human Service
  Kansas State University
  Manhattan, KS
- Sarah Niemeyer
  Clinical Director
  Amethyst, Inc.
  Columbus, OH
- Thomas A. Peltz, M.Ed.
  Therapist/Licensed Mental Health Counselor
  Certified Addiction Specialist
  Private Practice
  Beverly Farms, MA
- Karen Pressman, M.S.W., CADAC, LACDI
  Director, Planning and Development
  Bureau of Substance Abuse Services
  Massachusetts Department of Public Health
  Boston, MA
- Melissa V. Rael, USPHS
  Senior Program Management Officer
  Co-Occurring and Homeless Branch
  Division of State and Community Assistance
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Lawrence D. Rickards, Ph.D.
  Public Health Advisor
  Center for Mental Health Services
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Alice F. Roeling
  OAD Inpatient Facility Manager
  The Springs of Recovery Adolescent Program
  Greenwall Springs, LA
- James Rowan, M.A.
  Program Manager
  Case Management and Offender Services
  Arapahoe House, Inc.
  Thornton, CO
- JoAnn Y. Sacks, Ph.D.
  Deputy Director, CIRP
  National Development and Research Institutes, Inc.
  New York, NY
- Darren C. Skinner, M.S.W., Ph.D., LSW
  Division Director
  Co-Occurring Program
  Gaudenzia, Inc.
  Philadelphia, PA
- Mickey J.W. Smith, M.S.W.
  Senior Policy Associate, Behavioral Health
  Program, Policy & Practice Unit
  Division of Professional Development & Advocacy
  National Association of Social Workers
  Washington, DC
- Richard T. Suchinsky, M.D.
  Associate Chief for Addictive Disorders and Psychiatric Rehabilitation
  Mental Health and Behavioral Sciences Services
  Department of Veterans Affairs
  Washington, DC
- Wilbur Woodis, M.A.
  Management Analyst
  Office of Clinical and Preventive Services
  Division of Behavioral Health
  Indian Health Service
  Office of Public Health
  U.S. Department of Health and Human Services
  Rockville, MD