# SAMHSA Resource Panel

- John Bailey
  Special Expert
  Office of Policy, Planning, and Budget
  Office of the Administrator
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Shirley Beckett, NCAC II
  Certification Administrator
  National Association of Alcohol and Drug Abuse Counselors
  Washington, DC
- Danny Brom, Ph.D.
  Director
  The Israel Center for the Treatment of Psychotrauma
  Latner Institute for the Study of Social Psychiatry and Psychotherapy
  Israel
- Ling Chin, M.D.
  Chief, Clinical Science
  Center for the Clinical Trials Network
  National Institute on Drug Abuse
  National Institutes of Health
  Bethesda, MD
- Carol Coley, M.S., USPHS
  Senior Program Management Officer
  Division of State and Community Assistance
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Christina Currier
  Public Health Analyst
  Office of Evaluation, Scientific Analysis and Synthesis
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Marlene EchoHawk, Ph.D.
  Health Science Administrator
  Division of Health
  Indian Health Service
  U.S. Department of Health and Human Services
  Rockville, MD
- Jill Shepard Erickson, M.S.W., ACSW
  Center for Mental Health Services
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Angela M. Gonzalez, Ph.D., CDR, USPHS
  Special Programs Development Branch-Refugee Mental Health Program
  Division of Prevention, Traumatic Stress, and Special Programs
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Jacqueline Hendrickson, M.S.W., LCSW-C
  Public Health Advisor
  Division of Pharmacologic Therapies
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Michael Hilton, Ph.D.
  Health Science Administrator
  Division of Clinical and Prevention Research
  National Institute of Alcohol Abuse and Alcoholism
  National Institutes of Health
  Bethesda, MD
- Kenneth J. Hoffman, M.D., M.P.H.
  Medical Director
  TRICARE Management Activity
  Military Health System-Population Health Programs
  Department of Defense, Health Affairs
  Falls Church, VA
- Kirk E. James, M.D.
  Special Expert
  Systems Improvement Branch
  Division of Services Improvement
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Hendree E. Jones, Ph.D.
  Assistant Professor
  Department of Psychiatry and Behavioral Sciences
  Johns Hopkins University Center
  Baltimore, MD
- Cindy Kleppinger, M.D.
  Center for the Clinical Trials Network
  National Institute on Drug Abuse
  National Institutes of Health
  Bethesda, MD
- David Liu, M.D.
  Center for the Clinical Trials Network
  National Institute on Drug Abuse
  National Institutes of Health
  Bethesda, MD
- Richard E. Lopez, J.D., Ph.D.
  Social Science Analyst
  Co-Occurring and Homeless Branch
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Sue Martone, M.P.A.
  Public Health Advisor
  Office of Disease Prevention and Health Promotion
  U.S. Department of Health and Human Services
  Washington, DC
- Dee S. Owens, M.P.A.
  Director
  Alcohol-Drug Information Center
  Indiana University
  Bloomington, IN
- Harold I. Perl, Ph.D.
  Chief, Health Services Research Branch
  Division of Clinical and Prevention Research
  National Institute of Alcohol Abuse and Alcoholism
  National Institutes of Health
  Bethesda, MD
- Melissa V. Rael, USPHS
  Senior Program Management Officer
  Division of State and Community Assistance
  Co-Occurring and Homeless Branch
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Lawrence D. Rickards, Ph.D.
  Co-Occurring Disorders Program Manager
  Homeless Programs Branch
  Division of Knowledge Development and Systems Change
  Center for Mental Health Services
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Cecilia Rivera-Casale, Ph.D.
  Senior Project Officer
  Center for Mental Health Services
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Terrence Schomburg, Ph.D.
  Team Leader
  Division of State and Community Assistance
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Richard T. Suchinsky, M.D.
  Associate Chief for Addictive Disorders and Psychiatric Rehabilitation
  Mental Health and Behavioral Sciences Services
  Department of Veterans Affairs
  Washington, DC
- Beth A. Weinman, M.A.
  Coordinator
  National Drug Abuse Programs
  Correctional Programs Division-Services Branch
  U.S. Department of Justice
  Washington, DC
- Penelope P. Ziegler, M.D.
  Head, Treatment Section
  American Academy of Addiction Psychiatry
  Williamsburg, VA