# Organizational Assessment for Trauma-Informed Care

The following two resources are organizational assessments, which represent a key strategy in developing or re-evaluating trauma-informed services. The first assessment, presented by the University of South Florida, College of Behavioral and Community Sciences (2012), is designed for staff or key stakeholders. The second assessment comes from the Trauma-Informed Organizational Toolkit for Homeless Services (Guarino, Soares, Konnath, Clervil & Bassuk, 2009) and is a consumer version. There are several other assessment tools available, including Fallot and Harris’s Creating Cultures of Trauma-Informed Care (CCTIC): A Self Assessment and Planning Protocol (2009).

## Staff or Key Stakeholder Organizational Assessment Tool

University of South Florida, College of Behavioral and Community Sciences (2012). Creating Trauma-Informed Care Environments: An Organizational Self-Assessment. Available: http://www.cfbhn.org/assets/TIC/youthresidentialself%20assess%20Fillable%20FORM%20%282%29.pdf

## Consumer Version: Organizational Assessment Tool

Guarino, K., Soares, P., Konnath, K., Clervil, R., & Bassuk, E. (2009). Trauma-Informed Organizational Toolkit for Homeless Services. Rockville, MD: Center for Mental Health Services, Substance Abuse and Mental Health Services Administration, and the Daniels Fund, the National Child Traumatic Stress Network, and the W.K. Kellogg Foundation. See: pp. 82–93. Available: http://www.familyhomelessness.org/media/90.pdf