# Consumer Materials

The following are samples of available consumer materials relating to trauma-informed care and traumatic stress. There is a plethora of consumer information available to meet the immediate and long-term needs of consumers of behavioral health services affected by trauma. In order to not waste effort creating new materials for your client’s concerns, it is advisable to explore current science-informed resources. In most cases, consumer materials are already available and easily accessible for free.

AfterDeployment.org (2010). Just the Facts: Resilience. Available: http://afterdeployment.org/sites/default/files/pdfs/client-handouts/resilience-understanding.pdf

This Web site provides resources to address symptoms related to traumatic stress in addition to other postdeployment adjustment issues. This site provides information and handouts on resilience, triggers, and other trauma-related topics. It is appropriate for service members as well as civilians.

Blanch, A., Filson, B., & Penny, D. (2012). Engaging Women in Trauma-Informed Peer Support: A Guidebook. Available: http://www.nasmhpd.org/publications/engagingwomen.aspx

This draft technical assistance guide was created by the National Center for Trauma-Informed Care (NCTIC) and developed under contract with the National Association of State Mental Health Program Directors. This publication is designed to help make trauma-informed peer support available to women who are trauma survivors and who receive or have received behavioral health services. It is a resource for peers providing support in these or other settings who want to learn how to use trauma-informed principles in supporting women or in the peer support groups. It has been a resource used in the delivery of technical assistance through NCTIC.

Brymer, M., Jacobs, A., Layne, C., Pynoos, R., Ruzek, J., Steinberg, A., et al. (2006). Appendix E: Handouts. Psychological First Aid: Field Operations Guide. Available: http://www.ptsd.va.gov/professional/manuals/manual-pdf/pfa/PFA_Appx_E_handouts.pdf

Developed jointly with the National Child Traumatic Stress Network and the National Center for PTSD, this curriculum provides a science-informed approach to psychological first aid for response workers. The goals of this module are to assist survivors in the immediate aftermath of disaster and/or terrorism, reduce initial distress, and foster short-and long-term adaptive functioning. This link provides specific survivor-oriented material, such as strategies in seeking and giving support, education on common immediate reactions, and parental tips for children across developmental stages.

Center for Mental Health Services (2002). Dealing with the Effects of Trauma-A Self-Help Guide. Available: http://store.samhsa.gov/shin/content//SMA-3717/SMA-3717.pdf

This self-help guide gives practical information and tools to address and manage symptoms and other consequences of traumatic stress. It provides education on a variety of topics, including trauma-related symptoms, advice on the key ingredients of quality care, barriers to recovery, and practical strategies to enhance recovery and manage difficult emotions.

Center for Mental Health Services, Substance Abuse and Mental Health Services Administration (2005). Roadmap to Seclusion and Restraint Free Mental Health Services. Available: http://store.samhsa.gov/product/Roadmap-to-Seclusion-and-Restraint-Free-Mental-Health-Services-CD-/SMA06-4055

This curriculum concerns the elimination of seclusion and restraint. It provides numerous handouts for consumers as well as staff. Several consumer handouts include common reactions to trauma, a trauma screening tool, and strategies to de-escalate agitation and distress.

Mead, S. (2008). Intentional Peer Support: An Alternative Approach. Sherry Mead Consulting. Available: http://www.intentionalpeersupport.org/apps/webstore/products/show/3408520

This interactive workbook is designed for individuals who are in peer support roles and those who use peer support services. It provides goals, tasks, competencies, and skills associated with peer support relationships and guidelines for first interviews.

Najavits, L. M. (2002). Seeking Safety: A Treatment Manual for PTSD and Substance Abuse. New York: Guilford Press.

This evidence-based practice for individuals who have a history of trauma and a substance use disorder provides not only guidelines for clinicians but handouts for individuals. The consumer materials include information on PTSD and substance abuse and their interrelationship, key principles of the Seeking Safety program, coping skills to support safety, and grounding exercises. For additional information and resources, go to http://www.seekingsafety.org.

National Center for PTSD, U.S. Department of Veterans Affairs (2010). Understanding PTSD. Available: http://www.ptsd.va.gov/public/understanding_ptsd/booklet.pdf

This booklet provides consumer information on posttraumatic stress, common traumatic stress symptoms, effective treatments, and resources. The National Center for PTSD also provides additional professional and public resources specific to trauma for veterans and civilians.

Sidran Institute (2012). Healing Self-Injury. Available: http://healingselfinjury.org/about.html

This Web site provides numerous resources for consumers and professionals to understand self-inflicted violence. It offers publication links, archived newsletters, and a current blog focused on self-harm.