# Trauma Resource List

## Introduction

As it would be difficult to include every organization focused on trauma, the list of resources in this appendix is not exhaustive; consequently, this list does not include books or other materials concerning the vast nature of this topic, but rather, it concentrates solely on online resources accessible to the public for free or as part of an organization membership. The inclusion of selected resources does not necessarily signify endorsement by the Substance Abuse and Mental Health Services Administration (SAMHSA), U.S. Department of Health and Human Services (HHS). Following these resources for adults is a list of resources focused on children and adolescents and a list of training opportunities.

Technology and Trauma: Using the Web To Treat PTSD

The role of the Internet in helping those who are experiencing posttraumatic stress disorder (PTSD) has expanded rapidly; there are numerous Web sites with toolkits and research publications for clinicians who treat clients with PTSD, as well as Web sites aimed at providing information and support for these individuals. The U.S. military has contributed to the field in developing these avenues— specifically, with interactive Web applications for use on home computers and smartphones.

- PTSD Coach is a smartphone application from the U.S. Department of Veterans Affairs (VA) to help people experiencing PTSD learn about and manage their symptoms (http://www.ptsd.va.gov/public/pages/ptsdcoach.asp).
- Afterdeployment.org is a Web site developed by the Defense Centers of Excellence project led by the National Center for Telehealth & Technology, with interactive workshops about PTSD, traumatic brain injury (TBI), anxiety, and depression, aimed at returning veterans (http://www.afterdeployment.org).
- T2 Virtual PTSD Experience, also developed by the National Center for Telehealth & Technology, is an application to be used within the popular online game Second Life as an interactive way of simulating how PTSD can be acquired within a combat environment, how PTSD may present itself to the person experiencing it, and how to seek effective treatment (http://www.t2health.org/vwproj).

## Resources for Adults

### Academy of Cognitive Therapy

- http://www.academyofct.org
  260 South Broad Street
  18th Floor
  Philadelphia, PA 19102
  Phone: 267-350-7683
  Email: info@academyofct.org

The Academy of Cognitive Therapy, a nonprofit organization, supports continuing education and research in cognitive therapy, provides a valuable resource in cognitive therapy for professionals and the public at large, and actively works toward the identification and certification of clinicians skilled in cognitive therapy. Certification is awarded to those individuals who, based on an objective evaluation, have demonstrated an advanced level of expertise in cognitive therapy. The Academy includes physicians, psychologists, social workers, and other mental health professionals from around the world. The Academy formed a Trauma Task Force after September 11, 2001, to disseminate information (available on their Web site) to help people around the world receive the best help possible following trauma.

### Addiction Technology Transfer Center Network

- http://www.attcnetwork.org/index.asp
  5100 Rockhill Road
  Kansas City, MO 64110
  Phone: 816-235-6888
  Email: networkoffice@attcnetwork.org

The Addiction Technology Transfer Center (ATTC) Network serves as a resource for students and professionals to identify international distance education opportunities for the substance abuse treatment field and as a free marketing venue for ATTC-approved sponsors of distance education courses. The ATTC Web site provides trauma-related resources that include case studies, information on working with returning veterans who have been exposed to trauma, and links to various publications on PTSD and secondary traumatic stress.

### Agency for Healthcare Research and Quality

- http://www.innovations.ahrq.gov/index.aspx
  540 Gaither Road
  Suite 2000
  Rockville, MD 20850
  Phone: 301-427-1104

The Agency for Healthcare Research and Quality (AHRQ) is the research arm of HHS, specializing in patient safety and quality improvement, outcomes and effectiveness of care, clinical practice and technology assessment, and healthcare organization and delivery systems. AHRQ also provides funding and technical assistance to health research and research training programs at many universities and institutions. AHRQ’s Web site provides links to research publications on PTSD and to other government publications and toolkits dealing with trauma-informed care.

### The American Academy of Experts in Traumatic Stress

- http://www.aaets.org
  203 Deer Road
  Ronkonkoma, NY 11779
  Phone: 631-543-2217
  Email: info@aaets.org

The American Academy of Experts in Traumatic Stress is a multidisciplinary network of professionals who are committed to the advancement of intervention for survivors of trauma. The Academy aims to identify expertise among professionals and across disciplines and to provide meaningful standards for those who work regularly with survivors. The Academy is committed to fostering a greater appreciation of the effects of common traumatic experiences (e.g., chronic illness, accidents, domestic violence, loss) in addition to large-scale disasters and catastrophes. The group’s aim is to help all victims to become survivors and, ultimately, to thrive.

### American Red Cross Disaster Services

- http://www.redcross.org/what-we-do/disaster-relief
  American Red Cross National Headquarters
  2025 E Street, NW
  Washington, DC 20006
  Phone: 202-303-4498

Red Cross disaster relief focuses on meeting people’s immediate emergency disaster-caused needs. When a disaster threatens or strikes, the Red Cross provides shelter, food, and health and mental health services to address basic human needs. In addition to these services, the core of Red Cross disaster relief is the assistance given to individuals and families affected by disaster to enable them to resume their normal daily activities independently. Training opportunities are also provided.

### Anxiety and Depression Association of America

- http://www.adaa.org
  8701 Georgia Avenue #412
  Silver Spring, MD 20910
  Phone: 240-485-1001

The Anxiety and Depression Association of America (ADAA) is the only national, nonprofit membership organization dedicated to informing the public, healthcare professionals, and legislators that anxiety disorders are real, serious, and treatable. ADAA promotes the early diagnosis, treatment, and cure of anxiety disorders and is committed to improving the lives of the people who have them. The ADAA Web site provides information about the symptoms of PTSD and how it can be treated, in addition to offering a PTSD self-screening tool.

### Association for Behavioral and Cognitive Therapies

- http://www.abct.org
  305 7th Avenue
  16th Floor
  New York, NY 10001
  Phone: 212-647-1890
  Fax: 212-647-1865

The Association for Behavioral and Cognitive Therapies is a professional, interdisciplinary organization concerned with the application of behavioral and cognitive science to understanding human behavior, developing interventions to enhance the human condition, and promoting the appropriate use of these interventions. The association’s Web site includes resources for the public and for professionals on trauma and disaster-related problems, a clinical referral directory, and other resources and training opportunities in behavioral therapy.

### Association of Traumatic Stress Specialists

- http://www.atss.info
  88 Pompton Avenue
  Verona, NJ 07044
  Phone: 973-559-9200
  Email: Admin@atss.info

The Association of Traumatic Stress Specialists is an international membership organization that offers three distinct board certifications to qualified individuals who provide services, intervention, response, and/or treatment in the field of traumatic stress. The Association is dedicated to improving the quality of life of all individuals throughout the world who have been affected by traumatic events. Membership represents those who serve survivors of natural disasters, terrorist attacks, injuries and deaths related to serving in the line of duty or to school and workplace violence; veterans; refugees; victims of crime; Holocaust survivors; those affected and exploited by political persecution; and others who have experienced traumatic stress injuries.

### Center for Anxiety and Related Disorders

- http://www.bu.edu/card
  648 Beacon Street
  6th Floor
  Boston, MA 02215
  Phone: 617-353-9610

The Center for Anxiety and Related Disorders (CARD) at Boston University is a clinical and research center dedicated to advancing knowledge and providing care for anxiety, mood, eating, sleep, and related disorders. CARD’s Web site offers information regarding PTSD and research publications on trauma and anxiety, in addition to linking to toolkits from the National Child Traumatic Stress Network’s Adolescent Traumatic Stress and Substance Abuse Program.

### Center for the Study of Traumatic Stress

- http://www.cstsonline.org
  Uniformed Services University of the Health Sciences
  Department of Psychiatry
  4301 Jones Bridge Road
  Bethesda, MD 20814-4799
  Phone: 301-295-2470
  Fax: 301-319-6965

The Center for the Study of Traumatic Stress (CSTS) is a federally funded organization established by the Military Health System in 1987 to address Department of Defense concerns regarding health risks and concerns resulting from the traumatic impact of the use of weapons of mass destruction in combat, acts of terrorism and hostage events, combat and peacekeeping operations, natural disasters, and assaults or accidents occurring in both uniformed and civilian communities. CSTS primarily serves members of the armed forces, along with their children and families.

### Center for Culture, Trauma and Mental Health Disparities

- http://www.semel.ucla.edu/cctmhd
  UCLA Semel Institute of Neuroscience & Biobehavioral Sciences
  760 Westwood Plaza
  Los Angeles, CA 90024
  Phone: 310-794-9929

The Collaborative Center for Trauma and Mental Health Disparities at the University of California Los Angeles is a multiethnic and multidisciplinary group that focuses on conducting research and providing training that pertains to trauma in minority populations.

### Council of State Governments Justice Center—Mental Health

- http://csgjusticecenter.org/jc/category/mental-health
  100 Wall Street
  20th Floor
  New York, NY 10005
  Phone: 212-482-2320
  Fax: 212-482-2344
  Email: consensusproject@csg.org

The Consensus Project is part of the Council of State Governments Justice Center and partners with other organizations, such as SAMHSA’s GAINS Center, working to improve outcomes for people, including juveniles, with mental illnesses involved with the criminal justice system. The Consensus Project offers a webinar on trauma services in the criminal justice system and on child trauma and juvenile justice, as well as a local programs database.

### Dart Center for Journalism and Trauma

- http://www.dartcenter.org
  Columbia University
  Graduate School of Journalism
  2950 Broadway
  New York, NY 10027
  Phone: 212-854-8056

The Dart Center is dedicated to improving media coverage of trauma, conflict, and tragedy. The Center also addresses the consequences of such coverage for those working in journalism and provides training and education via seminars, newsroom briefings and consultation on trauma issues, in addition to training for journalism educators and other trainers. The Dart Center Web site offers fact sheets, publications, and DVDs on request for use by journalists, educators, and clinicians.

### David Baldwin’s Trauma Information Pages

- http://www.trauma-pages.com
  Phone: 541-686-2598
  Email: dvb@trauma-pages.com

This Web site focuses primarily on emotional trauma and traumatic stress, including PTSD and dissociation, whether following individual traumatic experience(s) or a large-scale disaster. The site’s purpose is to provide information for clinicians and researchers in the traumatic stress field. Specifically, the focus is on both clinical and research aspects of trauma responses and their resolution.

### Disaster Technical Assistance Center

- http://www.samhsa.gov/dtac
  9300 Lee Highway
  Fairfax, VA 22031
  Phone: 800-308-3515
  Fax: 703-225-2338

SAMHSA has created the Disaster Technical Assistance Center (DTAC) to help States prepare for and respond to a wide range of potential catastrophes—both natural and human-caused disasters. DTAC primarily serves individuals and communities who are recovering from natural and human-caused disasters. It works in conjunction with the Federal Emergency Management Agency (FEMA) and SAMHSA’s Emergency Mental Health and Traumatic Stress Services Branch, using strengths-based, outreach-oriented principles conducted in nontraditional settings, as a supplement to programs already in place on a local level.

### EMDR Institute, Inc

- http://www.emdr.com
  P.O. Box 750
  Watsonville, CA 9507
  Phone: 831-761-1040
  Fax: 831-761-1204
  Email: inst@emdr.com

Eye Movement Desensitization and Reprocessing (EMDR) is an information-processing therapy that uses an eight-phase approach. (See the description in Part 1, Chapter 6.) The Web site presents background and descriptive information about this approach to treatment and lists training opportunities, references, and networking groups.

### The Federal Emergency Management Agency

- http://www.fema.gov
  500 C Street SW
  Washington, DC 20472
  Phone: 202-646-2500

The Federal Emergency Management Agency, a formerly independent agency that became part of the Department of Homeland Security in March 2003, is tasked with responding to, planning for, recovering from, and mitigating against disasters. FEMA can trace its beginnings to the Congressional Act of 1803. This Act, generally considered the first piece of disaster legislation, provided assistance to a New Hampshire town following an extensive fire. In the century that followed, ad hoc legislation was passed more than 100 times in response to hurricanes, earthquakes, floods, and other natural disasters.

### The International Critical Incident Stress Foundation, Inc

- http://www.icisf.org
  3290 Pine Orchard Lane
  Suite 106
  Ellicott City, MD 21042
  Phone: 410-750-9600
  Fax: 410-750-9601
  Email: info@icisf.org

The International Critical Incident Stress Foundation, Inc., is a nonprofit, open-membership foundation dedicated to the prevention and mitigation of disabling stress through the provision of education, training, and support services for all emergency services professions; continuing education and training in emergency mental health services for psychologists, psychiatrists, social workers, and licensed professional counselors; and consultation in the establishment of crisis and disaster response programs for varied organizations and communities worldwide.

### International Society for the Study of Trauma and Dissociation

- http://www.issd.org
  8400 Westpark Drive
  Second Floor
  McLean, VA 22102
  Phone: 703-610-9037
  Fax: 703-610-0234
  Email: info@isst-d.org

The Society is a nonprofit professional association organized for the purposes of information sharing and international networking of clinicians and researchers; providing professional and public education; promoting research and theory about dissociation; and promoting research and training in the identification, treatment, and prevention of dissociative disorders. The Society offers courses in its Dissociative Disorders Psychotherapy Training Program.

### The International Society for Traumatic Stress Studies

- http://www.istss.org
  111 Deer Lake Road
  Suite 100
  Deerfield, IL 60015
  Phone: 847-480-9028
  Fax: 847-480-9282

The International Society for Traumatic Stress Studies (ISTSS) was founded in 1985 for professionals to share information about the effects of trauma. ISTSS is dedicated to the discovery and dissemination of knowledge about policy, program, and service initiatives that seek to reduce traumatic stressors and their immediate and long-term consequences. ISTSS provides a forum for the sharing of research, clinical strategies, public policy concerns, and theoretical formulations on trauma in the United States and around the world.

### National Alliance on Mental Illness

- http://www.nami.org
  3803 N. Fairfax Dr.
  Suite 100
  Arlington, VA 22203
  Phone: 703-524-7600
  Fax: 703-524-9094

The National Alliance on Mental Illness (NAMI) is a nonprofit advocacy group founded in 1979 to raise awareness and provide essential and free education, advocacy, and support group programs for people living with mental illness and their loved ones. NAMI operates at the local, State, and national levels, with each level of the organizations providing education, information, support, and advocacy for those with mental illness and their support system. NAMI has developed a Trauma Toolkit and includes a series of lectures for mental health professionals about trauma.

### National Association of State Alcohol and Drug Abuse Directors, Inc

- http://www.nasadad.org
  1025 Connecticut Ave NW
  Suite 605
  Washington, DC 20036
  Phone: 202-293-0090
  Fax: 202-293-1250
  Email: dcoffice@nasadad.org

The National Association of State Alcohol and Drug Abuse Directors, Inc. (NASADAD) is a private, not-for-profit educational, scientific, and informational organization. NASADAD’s basic purpose is to foster and support the development of effective alcohol and drug abuse prevention and treatment programs throughout every State. NASADAD offers a policy brief with regards to trauma and substance use/abuse in the wake of natural or human-made disasters.

### National Association of State Mental Health Program Directors

- http://www.nasmhpd.org
  66 Canal Center Plaza
  Suite 302
  Alexandria, VA 22314
  Phone: 703-739-9333
  Fax: 703-548-9517

The National Association of State Mental Health Program Directors (NASMHPD; pronounced “NASH-pid”) is a nonprofit organization dedicated to serving the needs of the Nation’s public mental health system through policy development, information dissemination, and technical assistance. NASMHPD represents the $23 billion public mental health service delivery system. As a private, not-for-profit 501(c)(3) membership organization, NASMHPD helps set the agenda and determine the direction of State mental health agency interests across the country, historically including State mental health planning, service delivery, and evaluation. The principal programs operated, funded, and/or regulated by NASMHPD members serve people who have serious mental illnesses, developmental disabilities, and/or substance use disorders. NASMPHD has launched a Technical Assistance Coordinating Center in response to the Alternatives to Restraint and Seclusion State Infrastructure Grant Project, an initiative of SAMHSA’s Center for Mental Health Services, designed to promote the implementation and evaluation of best practice approaches to preventing and reducing the use of seclusion and restraint in mental health settings.

### National Center for Injury Prevention and Control

- http://www.cdc.gov/injury
  1600 Clifton Road
  Atlanta, GA 30333
  Phone: 800-232-4636
  Email: cdcinfo@cdc.gov

The National Center for Injury Prevention and Control (NCIPC) was established by the Centers for Disease Control and Prevention in 1992. Through research, surveillance, implementation of evidence-based strategies, capacity building, and communication activities, NCIPC works to reduce morbidity, disability, mortality, and costs associated with injuries and violence. NCIPC is the lead U.S. Federal agency for nonoccupational injury prevention.

### National Center for PTSD

- http://www.ptsd.va.gov
  810 Vermont Avenue NW
  Washington, DC 20420
  Phone: 802-296-6300
  Email: ncptsd@va.gov

The National Center for PTSD (NCPTSD) was created within the Department of Veterans Affairs in 1989 in response to a Congressional mandate to address the needs of veterans with military-related PTSD. Its mission is to advance the clinical care and social welfare of America’s veterans through research, education, and training in the science, diagnosis, and treatment of PTSD and stress-related disorders. Its Web site is provided as an educational resource concerning PTSD and other enduring consequences of traumatic stress. The NCPTSD Web site has information about instruments to measure trauma exposure, risk and resilience factors for PTSD, self-report instruments, and interview schedules. Training opportunities are listed at http://www.ptsd.va.gov/about/training/training-programs.asp.

### National Center for Telehealth and Technology

- http://www.t2health.org
  9933C West Hayes Street
  Joint Base Lewis-McChord, WA 98431
  Phone: 253-968-1914
  Fax: 253-968-4192
  Email: AskUs@t2health.org

The National Center for Telehealth and Technology is a Federal agency founded by the Department of Defense as part of the Military Health System. It primarily serves veterans and active-duty military personnel who are experiencing adverse health effects due to TBI and PTSD, as well as military children who are coping with their parents’ deployment, through the use of technology (e.g., mobile phone applications, deployable telehealth centers).

### National Center for Trauma-Informed Care

- http://www.samhsa.gov/nctic
  66 Canal Center Plaza
  Suite 302
  Alexandria, VA 22314
  Phone: 866-254-4819
  Fax: 703-548-9517
  Email: NCTIC@NASMHPD.org

The National Center for Trauma-Informed Care (NCTIC) is a Federal center established by SAMHSA in 2005 to offer consultation, technical assistance, education, outreach, and resources to support trauma-informed care in publicly-funded systems and programs. NCTIC primarily serves those who are already receiving services from the behavioral health system and is focused on helping behavioral health services and programs to become more aware of the impact of trauma among consumers, to adapt services to incorporate trauma-informed practices, and to help raise awareness of practices or processes that are more likely to retraumatize consumers.

### National Center for Victims of Crime

- http://www.victimsofcrime.org
  2000 M Street NW
  Suite 480
  Washington, DC 20036
  Phone: 202-467-8700
  Fax: 202-467-8701
  Email: webmaster@ncvc.org

The National Center for Victims of Crime (NCVC) is a nonprofit organization funded partially by Federal grants from the Department of Justice. It was founded in 1985 and originally known as the Sunny Von Bulow National Victim Advocacy Center. NCVC is a resource center for those affected by violent crimes and also provides training and education for behavioral health service providers.

### National Center on Domestic Violence, Trauma & Mental Health

- http://www.nationalcenterdvtraumamh.org/
  Phone: 312-726-7020
  Fax: 312-726-7022

The National Center on Domestic Violence, Trauma & Mental Health was established in 2005 through a grant from the Family Violence Prevention and Services Program, HHS. The Center’s mission is to promote accessible, culturally relevant, and trauma-informed responses to domestic violence and other lifetime trauma so that survivors and their children can access the resources that are essential to their safety and well-being; this is achieved by providing training and online resources to mental health and substance abuse treatment providers and developing policies to improve system responses to domestic violence survivors and their children.

### National Center on Elder Abuse

- http://www.ncea.aoa.gov
  University of California–Irvine
  Program in Geriatric Medicine
  101 The City Drive South, 200 Building
  Orange, CA 92868
  Phone: 855-500-3537
  Email: ncea-info@aoa.hhs.gov

The National Center on Elder Abuse (NCEA), part of the U.S. Administration on Aging, serves as a national resource center dedicated to the prevention of elder mistreatment. NCEA provides information to both mental health professionals and the general public and also provides technical assistance and training to States and community-based organizations.

### National Center on Family Homelessness

- http://www.familyhomelessness.org
  200 Reservoir Street
  Suite 200
  Needham, MA 02494
  Phone: 617-964-3834
  Fax: 617-244-1758
  Email: info@familyhomelessness.org

The National Center on Family Homelessness (NCFH) was founded in 1988 and is a nonprofit organization that conducts research and creates public awareness about the special needs of families experiencing homelessness. NCFH primarily serves veterans who are homeless and their families and young mothers who are homeless with their children. NCFH has developed a Trauma-Informed Organizational Toolkit for Homeless Services.

### National Coalition Against Domestic Violence

- http://www.ncadv.org
  1 Broadway
  Suite B210
  Denver, CO 80203
  Phone: 303-839-1852
  Fax: 303-831-9251
  Email: mainoffice@ncadv.org

The National Coalition Against Domestic Violence (NCADV) is an advocacy group founded in 1978 and acts as a national information and referral center for the general public, media, survivors of domestic violence and their children, and allied and member agencies and organizations. NCADV also works to influence legislation that would provide protection for survivors of domestic violence and their families and provide funding to shelters, healthcare centers, and other organizations.

### National Council for Behavioral Health

- http://www.thenationalcouncil.org
  1701 K Street NW
  Suite 400
  Washington, DC 20006
  Phone: 202-684-7457
  Email: communications@thenationalcouncil.org

The National Council for Behavioral Health is a national community behavioral health advocacy organization, formed in 1970, to conduct Federal advocacy activities, representing the industry on Capitol Hill and before Federal agencies. It also offers a national consulting service program, various publications, and an annual training conference. The National Council Magazine, 2011, Issue 2, focuses on trauma-informed behavioral health services. The National Council has offered a Learning Community for Adoption of Trauma-Informed Practices, funded by SAMHSA.

### National Institute on Drug Abuse

- http://drugabuse.gov
  National Institute on Drug Abuse
  National Institutes of Health
  6001 Executive Boulevard
  Room 5213, MSC 9561
  Bethesda, MD 20892-9561
  Phone: 301-443-1124
  Email: information@nida.nih.gov

The National Institute on Drug Abuse’s (NIDA) mission is to lead the Nation in bringing the power of science to bear on drug abuse and addiction. NIDA’s goal is to ensure that science, not ideology or anecdote, forms the foundation for all of the Nation’s drug abuse reduction efforts. NIDA was established in 1974, and in October 1992 it became part of the National Institutes of Health (NIH), HHS. The Institute is organized into divisions and offices, each of which plays an important role in programs of drug abuse research. NIDA has an ongoing research program on women’s health and sex/gender differences, including the gathering of information on trauma and substance abuse.

### National Institute of Mental Health

- http://www.nimh.nih.gov
  National Institute of Mental Health
  Science Writing, Press, and Dissemination Branch
  6001 Executive Boulevard
  Room 8184, MSC 9663
  Bethesda, MD 20892-9663
  Phone: 301-443-4513
  Fax: 301-443-4279
  Email: nimhinfo@mail.nih.gov

The National Institute of Mental Health (NIMH) is one of the 27 component institutes of NIH, the Federal Government’s principal biomedical and behavioral research agency that is part of HHS. NIMH’s mission is to reduce the burden of mental illness and behavioral disorders through research on mind, brain, and behavior. This public health mandate demands that NIMH use science to achieve better understanding, treatment, and eventually, prevention of these disabling conditions that affect millions of Americans. NIMH offers publications and podcasts related to traumatic events and PTSD.

### National Registry for Evidence-Based Programs and Practices

- http://www.nrepp.samhsa.gov
  Phone: 866-436-7377
  Email: nrepp@samhsa.hhs.gov

SAMHSA’s National Registry for Evidence-Based Programs and Practices (NREPP) is a searchable online registry of more than 300 interventions supporting mental health promotion, substance abuse prevention, and mental health and substance abuse treatment. NREPP offers several interventions that address trauma and PTSD.

### National Sexual Violence Resource Center

- http://www.nsvrc.org
  123 North Enola Drive
  Enola, PA 17025
  Phone: 717-909-0710
  Fax: 717-909-0714

The National Sexual Violence Resource Center (NSVRC) was founded by the Pennsylvania Coalition Against Rape in 2000 and is partially federally funded by grants from the Centers for Disease Control and Prevention. NSVRC advocates for changes in Federal and State legislation to further the goal of ending sexual violence in all communities, in addition to collecting and disseminating a wide range of resources on sexual violence, including statistics, research, position statements, statutes, training curricula, prevention initiatives and program information. NSVRC does not provide direct services to survivors of sexual violence but acts as a resource to support these services.

### National Trauma Consortium

- http://www.nationaltraumaconsortium.org
  520 Ralph Street
  Sarasota, FL 34242
  Phone: 941-312-9795

The National Trauma Consortium (NTC) is a clearinghouse for information about trauma and emerging best practices in trauma treatment and services and, in addition, offers training and consultation services. NTC also provides resources in the form of downloadable publications and links to other organizations related to mental health and trauma.

### National Voluntary Organizations Active in Disasters

- http://www.nvoad.org
  1501 Lee Highway
  Suite 170
  Arlington, VA 22209-1109
  Phone: 703-778-5088
  Fax: 703-778-5091
  Email: info@nvoad.org

National Voluntary Organizations Active in Disasters (NVOAD) coordinates planning efforts by many voluntary organizations responding to disaster. Member organizations provide more effective service and less duplication by getting together before disasters strike. Once disasters occur, NVOAD or an affiliated State VOAD encourages members and other voluntary agencies to convene on site. This cooperative effort has proven to be the most effective way for a wide variety of volunteers and organizations to work together in a crisis. NVOAD’s principles are cooperation, coordination, communication, education, mitigation, convening mechanisms, and outreach.

### Office for Victims of Crime Training and Technical Assistance Center

- https://www.ovcttac.gov/
  9300 Lee Highway
  Fairfax, VA 22031-6050
  Phone: 866-682-8822
  TTY: 866-682-8880
  Fax: 703-279-4673
  Email: TTAC@ovcttac.org

The Office for Victims of Crime Training and Technical Assistance Center provides comprehensive, quality technical assistance and training resources to victims’ service providers and allied professionals. Its mission is to support the development of the field by increasing the Nation’s capacity to provide crime victims with skilled, capable, and sensitive assistance. Its core functions are needs assessment, capacity building, evaluation, and reporting.

### Rape, Abuse & Incest National Network

- http://www.rainn.org
  1220 L Street NW
  Suite 505
  Washington, DC 20005
  Phone: 202-544-1034
  Email: info@rainn.org

The Rape, Abuse & Incest National Network (RAINN) is a nonprofit organization, founded in 1994, that is partially funded by a grant from the Office for Victims of Crime, Office of Justice Programs, U.S. Department of Justice. RAINN provides support for survivors of sexual assault via a telephone hotline and an online hotline and works with the Department of Defense (DoD) to provide a hotline for members of the DoD community who have experienced sexual assault.

### SAMHSA’s Tribal Training and Technical Assistance Center

- http://beta.samhsa.gov/tribal-ttac
  201 Corporate Drive
  Suite 800
  Landover, MD 20785
  Phone: 240-650-0257
  Email: TA-Request@tribaltechllc.com

SAMHSA’s Tribal Training and Technical Assistance Center (Tribal TTAC) is committed to providing comprehensive broad, focused, and/or intensive training and technical assistance to federally recognized Tribes and other American Indian and Alaska Native communities seeking to address and prevent mental and substance use disorders and suicide while promoting mental health. The goal of the Tribal TTAC is to use a culturally relevant, evidence-based, holistic approach to support Native communities in their self-determination efforts through infrastructure development, capacity building, and program planning and implementation.

### Sanctuary Model

- http://www.sanctuaryweb.com
  Phone: 888-538-3124

The goals of the Sanctuary Model include increasing the perceived sense of community/cohesiveness; the degree of social immunity to the spread of violence; the capacity for social learning; the making of decisions democratically and the sharing of responsibility in solving problems and resolving conflicts; the ability to deal with complexity; opportunities for all clients and staff members to experience a truly safe and connected community; opportunities for troubled clients to have corrective emotional, relational, and environmental experiences; and recovery, healing, and growth.

### Seeking Safety

- http://www.seekingsafety.org
  Treatment Innovations
  28 Westbourne Road
  Newton Centre, MA 02459
  Phone: 617-299-1610
  Fax: 617-701-1295
  Email: info@seekingsafety.org

This Web site provides information about Seeking Safety, a psychotherapeutic intervention for treating trauma, PTSD, and substance abuse. Seeking Safety is a present-focused therapy to help people attain safety from both PTSD and substance abuse. The treatment is also available as a book, which provides both client handouts and guidance for clinicians. The site includes topics included in the treatment program, sample materials, relevant empirical studies, and supplementary articles.

### Sidran Institute

- http://www.sidran.org
  P.O. Box 436
  Brooklandville, MD 21022-0436
  Phone: 410-825-8888
  Fax: 410-560-0134
  Email: info@sidran.org

The Sidran Institute is a nationally focused nonprofit organization devoted to helping people who have experienced traumatic life events through education and advocacy. The Institute’s education and advocacy focuses on:

- The early recognition and treatment of trauma-related stress in children.
- The understanding of trauma and its long-term effect on adults.
- The strategies in engaging in mutual-help recovery for trauma survivors.
- The clinical methods and practices leading in aiding trauma victims.
- The development of public policy initiatives responsive to the needs of adult and child survivors of traumatic events.

### Substance Abuse and Mental Health Services Administration

- http://www.samhsa.gov
  1 Choke Cherry Lane
  Rockville, MD 20857
  Phone: 877-726-4727
  Fax: 240-221-4292
  Email: SAMHSAInfo@samhsa.hhs.gov

SAMHSA is the Federal agency within HHS charged with improving the quality and availability of prevention, treatment, and rehabilitative services to reduce illness, death, disability, and cost to society resulting from substance abuse and mental illness. The Emergency Mental Health and Traumatic Stress Services Branch, a branch of SAMHSA’s Center for Mental Health Services, works with FEMA to provide crisis counseling training and technical assistance to State and local mental health professionals. SAMHSA offers several publications regarding trauma and PTSD, as well as a publication focusing on creating a seclusion-free and restraint-free environment.

### Traumatic Stress Institute

- http://www.traumaticstressinstitute.org
  Klingberg Family Centers
  370 Linwood Street
  New Britain, CT 06052
  Phone: 860-224-9113

The Traumatic Stress Institute (TSI) works to increase understanding of the psychological impact of trauma and to help victims of violence restore meaning and wholeness to their lives. In meeting these goals, TSI is involved in clinical service, professional training, community education, and research. TSI offers forensic assessment and expert testimony, professional education, training opportunities, and publications. TSI developed the “Risking Connections” trauma treatment program and provides training in the use of this model.

### Tulane University Traumatology Institute

- http://sites.google.com/site/charlesfigley/Home/traumatologyinstitute
  Tulane School of Social Work
  6823 St. Charles Ave., Building 9
  New Orleans, LA 70118
  Phone: 800-631-8234
  Email: figley@tulane.edu

The Traumatology Institute, founded in 1996, brings together health and mental health professionals from a wide array of disciplines from throughout the United States and around the world to develop cutting-edge research, treatment approaches, and training programs in the field of traumatology. The Institute facilitates the development of knowledge about the traumatization experience of victims, survivors, and the professionals who serve them. The Traumatology Institute conducts research, education, and service activities toward reducing the deleterious effects of trauma on individuals, families, communities, and entire societies.

### Veterans Affairs PTSD Support Services

- http://www.ptsdsupport.net/va.html
  P.O. Box 5574
  Woodland Park, CO 80866
  Email: russ@ptsdsupport.net

The Department of Veterans Affairs Medical Centers provide a network of more than 100 specialized programs for veterans with PTSD, working closely in conjunction with the Veterans Web Site (http://www.vetcenter.va.gov) operated by VA’s Readjustment Counseling Service. Each specialized PTSD program offers veterans education, evaluation, and treatment conducted by mental health professionals from a variety of disciplines (such as psychiatry, psychology, social work, counseling, and nursing). See also: National Center for PTSD.

### White Bison Wellbriety Training Institute

- http://www.whitebison.org
  701 N. 20th Street
  Colorado Springs, CO 80904
  Phone: 877-871-1495
  Email: info@whitebison.org

White Bison is an American Indian nonprofit charitable organization that focuses on offering sobriety, recovery, addictions prevention, and wellness/Wellbriety learning resources to the Native American community nationwide. White Bison’s Wellbriety Training Institute provides training, tools, and resources for historical and intergenerational trauma to trainers and mental health professionals.

## Resources for Children and Adolescents

The following section provides resources that address the needs of children and adolescents who are affected by traumatic stress.

### American Academy of Child & Adolescent Psychiatry

- http://www.aacap.org
  3615 Wisconsin Avenue NW
  Washington, DC 20016-3007
  Phone: 202-966-7300
  Fax: 202-966-2891

The American Academy of Child & Adolescent Psychiatry (AACAP) is a national professional medical association dedicated to treating and improving the quality of life for children, adolescents, and families affected by mental, behavioral, and developmental disorders. AACAP distributes information to promote an understanding of mental illnesses and remove the shame associated with them, to advance efforts in prevention of mental illnesses, and to ensure proper treatment and access to services for children and adolescents.

### American Professional Society on the Abuse of Children

- http://www.apsac.org
  350 Poplar Avenue
  Elmhurst, IL 60126
  Phone: 630-941-1235
  Fax: 630-359-4274
  E-mail: apsac@apsac.org

The mission of the American Professional Society on the Abuse of Children (APSAC) is to enhance the ability of professionals to respond to children and families affected by abuse and violence. Among other initiatives, APSAC provides education and other sources of information to professionals who work in the child maltreatment and related fields.

### Anna Institute

- http://www.theannainstitute.org
  21 Ocean Street
  Rockland, ME 04841
  Email: afj@gwi.net

The Anna Institute was founded in memory of artist Anna Caroline Jennings; it focuses on educating both the public and mental health professionals about the effects of sexual abuse and trauma on children. The Anna Institute’s Web site provides articles on incorporating trauma-informed care into existing behavioral health models, presentations on childhood trauma and retraumatization, and handouts for teachers at primary and secondary schools.

### Caring for Every Child’s Mental Health Campaign

- http://www.samhsa.gov/children
  P.O. Box 2345
  Rockville, MD 20847-2345
  Email: nmhic-info@samhsa.hhs.gov

SAMHSA’s Caring for Every Child’s Mental Health communications campaign is a national public information and education operation. Its goals are to increase public awareness about the importance of protecting the mental health of young people; foster the recognition that many children have mental health problems; and encourage caregivers to seek early, appropriate treatment and services. It also strives to reduce discrimination associated with mental health problems. The campaign is a technical assistance program that is part of the Comprehensive Community Mental Health Services Program for Children and Their Families.

### Child Study Center

- http://www.aboutourkids.org
  One Park Avenue
  7th Floor
  New York, NY 10016
  Phone: 212-263-6622
  Email: webmaster@aboutourkids.org

The New York University Child Study Center Web site offers information to parents of children and adolescents with learning, behavioral, and emotional disorders, including PTSD and substance use disorders. An online newsletter is available. Its research initiatives advance understanding of the causes and treatments of child mental disorders, and these findings are integrated into clinical care to provide state-of-the-art service.

### Child Trauma Academy

- http://www.childtrauma.org
  5161 San Felipe
  Suite 320
  Houston, TX 77056
  Phone: 866-943-9779
  Email: cta@childtrauma.org

The mission of the Child Trauma Academy is to help improve the lives of traumatized and maltreated children. Through education, service delivery, and program consultation, the academy seeks to advance systems that educate, nurture, protect, and enrich these children.

### Child Trauma Institute

- http://www.childtrauma.com
  P.O. Box 544
  Greenfield, MA 01302-0544
  Phone: 413-774-2340
  Email: cti@childtrauma.com

The Child Trauma Institute provides training, consultation, information, and resources for those who work with trauma-exposed children, adolescents, and adults. The Web site has information for parents, publications for parents and professionals, and links to other child trauma Web sites.

### Child Welfare Information Gateway

- http://www.childwelfare.gov
  Children’s Bureau/ACYF
  1250 Maryland Avenue SW
  Eighth Floor
  Washington, DC 20024
  Phone: 800-394-3366
  Email: info@childwelfare.gov

The Child Welfare Information Gateway (CWIG) is a service of the Children’s Bureau in the Administration for Children and Families, part of HHS, which provides information to child welfare and mental health professionals about programs, research, laws and policies, training approaches, and statistics regarding child welfare, child abuse and neglect, and adoption. CWIG offers educators’ toolkits for preventing and responding to child abuse and neglect, a function to search State statutes about child abuse and neglect, and logic model builder toolkits for program administrators.

### Child Welfare League of America

- http://www.cwla.org
  1726 M Street NW
  Suite 500
  Washington DC, 20036
  Phone: 202-688-4200
  Fax: 202-833-1689

Through its member child welfare agencies, the Child Welfare League of America develops and disseminates practice standards as benchmarks for high-quality services that protect children and youth; promotes high-quality services through training, consultation, conferences, and publications; formulates and promotes public policies that contribute to the well-being of children and youth; ensures that all child welfare services are provided in a manner that demonstrates respect for cultural and ethnic diversity; and promotes open exchange of data, resources, and ideas within and across systems that serve children, youth, and families.

### Eunice Kennedy Shriver National Institute of Child Health and Human Development

- http://www.nichd.nih.gov/Pages/index.aspx
  31 Center Drive
  Building 31, Room 2A32
  Bethesda, MD 20892-2425
  Phone: 800-370-2943

Established in 1962, NIH’s National Institute of Child Health and Human Development (NICHD) focuses on human development processes from conception to later years. The Institute implements, conducts, and supports laboratory research, clinical trials, epidemiological research, and other studies that explore health processes and the impact of disabilities, diseases, and variations on the lives of individuals. NICHD sponsors training for scientists and healthcare providers to promote the goals of the Institute.

### National Center for Children Exposed to Violence

- http://www.nccev.org
  Yale Child Study Center
  230 South Frontage Road
  P.O. Box 207900
  New Haven, CT 06520-7900
  Phone: 877-496-2238
  Email: colleen.vadala@yale.edu

The National Center for Children Exposed to Violence (NCCEV) seeks to increase the capacity of individuals and communities to reduce the incidence and impact of violence on children and families; to train and support the professionals who provide intervention and treatment; and to increase professional and public awareness of the effects of violence on children, families, communities, and society. The Center’s Web site is a rich source of information. NCCEV is supported by grants from the Office of Juvenile Justice and Delinquency Prevention, the Department of Justice, SAMHSA, and the Department of Education.

### National Center on Substance Abuse and Child Welfare

- http://www.ncsacw.samhsa.gov
  P.O. Box 2345
  Rockville, MD 20847-2345
  Phone: 866-493-2758
  Email: ncsacw@cffutures.org

The National Center on Substance Abuse and Child Welfare (NCSACW) is an initiative of HHS and is jointly funded by SAMHSA’s Center for Substance Abuse Treatment and the Administration on Children, Youth and Families, Children’s Bureau’s Office on Child Abuse and Neglect. NCSACW seeks to develop and implement a comprehensive program of information gathering and dissemination, to provide technical assistance, and to develop knowledge that promotes effective practical, organizational, and systemic changes at the local, State, and national levels. Its Web site includes PowerPoint presentations, online tutorials and training, technical assistance presentations, and additional print resources.

### National Child Traumatic Stress Network

- http://www.nctsnet.org
  NCTSN—University of California, Los Angeles
  11150 W. Olympic Boulevard
  Suite 650
  Los Angeles, CA 90064
  Phone: 310-235-2633
  Fax: 310-235-2612

The National Child Traumatic Stress Network (NCTSN), currently comprising 54 treatment centers nationwide, is funded by SAMHSA’s Center for Mental Health Services through the Donald J. Cohen National Child Traumatic Stress Initiative (http://www.nctsnet.org/nccts/nav.do?pid=abt_hist) and coordinated by Duke University and the University of California, Los Angeles. The purpose of this congressionally mandated initiative is to improve the quality, effectiveness, provision, and availability of therapeutic services delivered to all children and adolescents experiencing traumatic events. NCTSN works with SAMHSA to raise public awareness of the effects of traumatic stress on children and families, and with other systems of care (including the health, mental health, education, law enforcement, child welfare, juvenile justice, and military family service systems) to ensure that there is a comprehensive trauma-informed continuum of accessible care. Additionally, NCTSN offers a list of evidence-based and promising practices.

### National Institute for Trauma and Loss in Children

- http://www.starrtraining.org/trauma-and-children
  42855 Garfield Road
  Suite 111
  Clinton Township, MI 48038
  Phone: 877-306-5256
  Fax: 586-263-4915
  Email: TLC@starrtraining.org

The National Institute for Trauma and Loss in Children provides school professionals, crisis intervention teams, medical and mental health professionals, child care professionals, and clinicians with trauma education, training, consultation, referral services, and trauma-specific intervention programs and resource materials needed to help those traumatized by violent or nonviolent trauma-inducing incidents.

### National Native Children’s Trauma Center

- http://iers.umt.edu/National_Native_Childrens_Trauma_Center
  Institute for Educational Research and Service
  McGill Hall 026
  The University of Montana
  Missoula, MT 59812-6376
  Phone: 406-243-5344
  Fax: 406-243-2197
  Email: iers@mso.umt.edu

The National Native Children’s Trauma Center (NNCTC) is a federally funded organization created by SAMHSA and affiliated with the National Child Traumatic Stress Network. It is run by the University of Montana. NNCTC offers trauma interventions and trainings to address trauma in American Indian/Alaska Native children, primarily through clinicians, Tribal programs, school systems, and community agencies.

## Training Opportunities

The following resources highlight various training and credentialing opportunities for behavioral health professionals interested in gaining more education in treating and providing services to those affected by trauma. It is not an exhaustive list, but provides a starting place for service providers looking for further training.

The Web site of the ISTSS has posted a directory of trauma-related academic and training opportunities (http://www.istss.org/LearningAboutTrauma.htm). It includes links to the institutions providing the programs. The Association for Traumatic Stress Specialists (http://www.atss.info) offers three levels of recognition for education and experience:

- Certified Trauma Specialist (CTS)—designed for counselors, clinicians, and treatment specialists who provide intervention services or individual, group, and/or family counseling. This certification requires 240 hours of education and training in trauma treatment, plus 2,000 hours of trauma counseling and intervention experience.
- Certified Trauma Responder (CTR)—designed for those who provide immediate trauma interventions. It requires a minimum of 40 hours of experience on a crisis or critical incident response team, an associate degree or a high school diploma with successful completion of disaster or critical incident stress debriefing training, and 72 hours of crisis response training.
- Certified Trauma Services Specialist (CTSS)—designed for those who provide immediate trauma intervention, crisis support, advocacy, or victim assistance. It requires 1 year of experience in a trauma-related field, plus specific training.

Some colleges and universities, such as the International Trauma Studies Program at New York University and the Center for Anxiety and Related Disorders at Boston University, provide specialty trauma training for mental health practitioners. The University of Missouri at St. Louis offers specialized training in trauma therapy or research at its Center for Trauma Recovery to students in its Clinical Psychology graduate program. The Center for the Treatment and Study of Anxiety at the University of Pennsylvania provides training for health professionals. The Department of Counseling at the University of Nevada, Las Vegas offers a graduate and undergraduate course on Trauma and Addiction; graduate students can receive training in trauma and addictions as part of the Advanced Graduate Certificate in Addiction Studies. The Medical University of South Carolina offers Web-based courses in trauma-focused cognitive–behavioral therapy (TF-CBT) and in using TF-CBT for childhood traumatic grief. Many universities have faculty members with expertise in trauma and trauma-related subjects, so that training can be accessed through many graduate programs.

The Addiction Technology Transfer Center (ATTC) Network, a resource established in 1993 by the SAMHSA’s Center for Substance Abuse Treatment, is a network of 14 independent regional centers with a national office. One of its programs provides long-distance education for clinicians on various topics. Among hundreds of self-paced, self-directed, and supervised courses available online (http://www.attcnetwork.org/learn/education/dasp.asp) are Substance Abuse Treatment for Trauma Survivors, Substance Abuse Treatment for Persons with Child Abuse and Neglect Issues, Chemical Dependency and Posttraumatic Stress Disorder, Clinical Self-Care for Addiction Counselors and Clinical Supervisors, Eye Movement Desensitization and Reprocessing, Battered Women and Addictions, and Posttraumatic Stress Disorder. ATTC training and educational opportunities are based on empirical research and are intended to bring science to service. Undoubtedly, more distance-learning courses in this specialized area of interest will be developed as professional attention to co-occurring disorders increases.

SAMHSA’s Center for Mental Health Services provides training for FEMA-approved crisis counseling programs using Stafford Act funding. These funding resources are available to select agencies designated to provide crisis counseling in the wake of a Presidential Disaster Declaration. Other funding for trauma training may be found through special programs of funding for target groups, such as those who provide mental health services and case management for victims of crime (e.g., Office for Victims of Crime in the U.S. Department of Justice; see p. 257).

The American Red Cross provides limited disaster mental health training. The focus of this training is to orient licensed mental health professionals to the Red Cross Disaster services system and their roles as volunteers.

The National Center for Post-Traumatic Stress Disorder was originally created in 1989 within the U.S. Department of Veterans Affairs (VA) to address the needs of veterans with military-connected PTSD. Its focus has since broadened to include trauma in general. The Center provides a variety of training opportunities for both VA and non-VA mental health personnel, including a PTSD 101 course developed specifically for clinicians who provide services to clients who have experienced trauma (see http://www.ptsd.va.gov/professional/index.asp).

Seeking Safety offers training in trauma, PTSD, and co-occurring disorders to mental health professionals on all levels, from counselors to nurses to administrators. The EMDR International Association (EMDRIA) provides training to clinicians for certification in EMDR via a curriculum including instruction, supervised practicum, and consultation; EMDRIA additionally provides basic training in the field, separate from the certification process. EMDR training is also provided by the EMDR Humanitarian Assistance Program, a nonprofit organization with a training-focused model to assist clinicians in treating trauma.

ISTSS was founded in 1985 to bring attention to the study, assessment, and treatment of traumatized people (http://www.istss.org). ISTSS is a professional society and provides face-to-face training during its annual meeting, especially through the preconference institutes. The ISTSS Web site offers numerous video and audio trainings for continuing education credits. ISTSS and the Figley Institute (http://www.figleyinstitute.com) have established best practice standards. The American Academy of Experts in Traumatic Stress provides training and certification in several different areas (http://www.aaets.org). Similarly, the International Society for the Study of Dissociation (http://www.issd.org) specializes in promoting therapies for dissociative disorders. In 2002, the Green Cross Academy of Traumatology (http://www.greencross.org) established a Commission on Accreditation of Traumatology Education Programs to increase and maintain the high standards in the education and training of traumatologists.