# Bibliography

Abrahams IA, Ali O, Davidson L, Evans AC, King JK, Poplawski P, et al. 2010. Philadelphia behavioral health services transformation: Practice guidelines for recovery and resilience oriented treatment. Philadelphia. Department of Behavioral Health and Intellectual Disability Services.
Adams RE, Figley CR, Boscarino JA. The Compassion Fatigue Scale: Its use with social workers following urban disaster. Research on Social Work Practice. 2008;18:238-250. [pmid: 18458750].
Adler AB, Litz BT, Castro CA, Suvak M, Thomas JL, Burrell L, et al. A group randomized trial of critical incident stress debriefing provided to U.S. peacekeepers. Journal of Traumatic Stress. 2008;21:253-263. [pmid: 18553407].
Administration on Children, Youth, and Families. 2002. Sexual abuse among homeless adolescents: Prevalence, correlates, and sequelae. Washington, DC. Administration on Children, Youth, and Families.
Advanced Trauma Solutions Inc. 2012. Trauma affect regulation: Guide for education & therapy. Farmington, CT. Advanced Trauma Solutions, Inc.
Allen JG. 2001. Traumatic relationships and serious mental disorders. New York. John Wiley & Sons Ltd.
American Psychiatric Association. 1980. Diagnostic and statistical manual of mental disorders. 3rd ed. Washington, DC. American Psychiatric Association.
American Psychiatric Association. 2000. Diagnostic and statistical manual of mental disorders. 4th ed, text rev. Washington, DC. American Psychiatric Association.
American Psychiatric Association. 2000. Position statement on therapies focused on memories of childhood physical and sexual abuse. Washington, DC. American Psychiatric Association.
American Psychiatric Association. 2012. G 03 posttraumatic stress disorder. Washington, DC. American Psychiatric Association.
American Psychiatric Association. 2012. Proposed draft revisions to DSM disorders and criteria. Washington, DC. American Psychiatric Association.
American Psychiatric Association. 2013. Diagnostic and statistical manual of mental disorders. 5th ed. Arlington, VA. American Psychiatric Association.
American Psychiatric Association. 2013. Highlights of changes from DSM-IV-TR to DSM-5. Arlington, VA. American Psychiatric Association.
American Psychological Association & The Ad Hoc Committee on Legal and Ethical Issues in the Treatment of Interpersonal Violence. 2003. Potential problems for psychologists working with the area of interpersonal violence. Washington, DC. American Psychiatric Association.
Anda RF, Felitti VJ, Bremner JD, Walker JD, Whitfield C, Perry BD, et al. The enduring effects of abuse and related adverse experiences in childhood. A convergence of evidence from neurobiology and epidemiology. European Archives of Psychiatry and Clinical Neuroscience. 2006;256(3):174-86. [pmid: 16311898].
Anda RF, Felitti VJ, Brown D, Chapman D, Dong M, Dube SR, et al. Insights into intimate partner violence from the adverse childhood experiences (ACE) study. The physician’s guide to intimate partner violence and abuse. 2006:77-88. Volcano, CA. Volcano Press.
Andreasen NC. Posttraumatic stress disorder: A history and a critique. Annals of the New York Academy of Sciences. 2010;1208:67-71. [pmid: 20955327].
Antony MM, Orsillo SM, Roemer L. 2001. Practitioner’s guide to empirically based measures of anxiety. New York. Plenum Press.
Arkowitz H, Miller WR, Westra HA, Rollnick S. Motivational interviewing in the treatment of psychological problems: Conclusions and future directions. Motivational interviewing in the treatment of psychological problems. 2008:324-342. New York. Guilford Press.
Auerbach S. Sleep disorders related to alcohol and other drug use. Graham AW, Schultz TK, Mayo-Smith MF, Ries RK, Wilford BB, editors. Principles of addiction medicine. 3rd ed. 2003:1179-1193. Chevy Chase, MD. American Society of Addiction Medicine.
Baer RA. Mindfulness training as a clinical intervention: A conceptual and empirical review. Clinical Psychology: Science and Practice. 2003;10:125-143.
Baker KG, Gippenreiter JB. Stalin’s purge and its impact on Russian families: A pilot study. Danieli Y, editor. International handbook of multigenerational legacies of trauma. 1998:403-434. New York. Plenum Press.
Bartone PT, Roland RR, Picano JJ, Williams T. Psychological hardiness predicts success in US Army Special Forces candidates. International Journal of Selection and Assessment. 2008;16:78-81.
Batten SV, Hayes SC. Acceptance and commitment therapy in the treatment of comorbid substance abuse and post-traumatic stress disorder: A case study. Clinical Case Studies. 2005;4:246-262.
Beck AT. 1993. Beck anxiety inventory. San Antonio, TX. The Psychological Corporation.
Beck AT, Rush AJ, Shaw BF, Emery G. 1979. Cognitive therapy of depression. New York. Guilford Press.
Beck AT, Steer RA, Brown GK. 1996. Beck depression inventory - II manual. San Antonio, TX. The Psychological Corporation.
Beck AT, Wright FD, Newman CF, Liese BF. 1993. Cognitive therapy of substance abuse. New York. Guilford Press.
Bell CC. Trauma, culture, and resiliency. Southwick SM, Litz BT, Charney D, Friedman MJ, editors. Resilience and mental health: Challenges across the lifespan. 2011:176-187. New York. Cambridge University Press.
Benedek DM, Ursano RJ. Posttraumatic stress disorder: From phenomenology to clinical practice. FOCUS: The Journal of Lifelong Learning in Psychiatry. 2009;7:160-175.
Bernard JM, Goodyear RK. 2009. Fundamentals of clinical supervision. 4th ed. Upper Saddle River, NJ. Merrill/Pearson.
Bernstein DP. Childhood trauma and drug addiction: Assessment, diagnosis, and treatment. Alcoholism Treatment Quarterly. 2000;18:19-30.
Bernstein EM, Putnam FW. Development, reliability, and validity of a dissociation scale. Journal of Nervous and Mental Disease. 1986;174:727-735. [pmid: 3783140].
Bills LJ. Using trauma theory and S.A.G.E. in outpatient psychiatric practice. Psychiatric Quarterly. 2003;74:191-203. [pmid: 12602833].
Blackburn C. 1995. Family and relapse. Counselor. Alexandria, VA. National Association of Alcoholism and Drug Abuse Counselors.
Blake D, Weathers F, Nagy L, Koloupek D, Klauminzer G, Charney D, et al. 1990. Clinician Administered PTSD Scale (CAPS). Boston. National Center for Post-Traumatic Stress Disorder.
Bleich A, Gelkopf M, Solomon Z. Exposure to terrorism, stress-related mental health symptoms, and coping behaviors among a nationally representative sample in Israel. Journal of the American Medical Association. 2003;290:612-620. [pmid: 12902364].
Bloom SL. 1997. Creating sanctuary: Toward the evolution of sane societies. New York. Routledge.
Bloom SL, Bennington-Davis M, Farragher B, McCorkle D, Nice-Martini K, Wellbank K. Multiple opportunities for creating sanctuary. Psychiatric Quarterly. 2003;74:173-190. [pmid: 12602832].
Bloom SL, Foderaro JF, Ryan R. 2006. S.E.L.F.: A trauma-informed psychoeducational group Curriculum. Retrieved on November 18, 2013, from: http://sanctuaryweb.com/PDFs_new/COMPLETE%20INTRODUCTORY%20MATERIAL.pdf.
Bober T, Regehr C. Strategies for reducing secondary or vicarious trauma: Do they work?. Brief Treatment and Crisis Intervention. 2006;6:1-9.
Bonanno GA. Loss, trauma, and human resilience: Have we underestimated the human capacity to thrive after extremely aversive events?. American Psychologist. 2004;29:20-28. [pmid: 14736317].
Bonanno GA, Mancini AD. Toward a lifespan approach to resilience and potential trauma. Southwick SM, Litz BT, Charney D, Friedman MJ, editors. Resilience and mental health: Challenges across the lifespan. 2011:120-134. New York. Cambridge University Press.
Bowman CG, Mertz E. A dangerous direction: Legal intervention in sexual abuse survivor therapy. Harvard Law Review. 1996;109:551-639.
Brady KT, Killeen T, Saladin ME, Dansky B, Becker S. Comorbid substance abuse and posttraumatic stress disorder: Characteristics of women in treatment. American Journal on Addictions. 1994;3:160-164.
Breslau N. Gender differences in trauma and posttraumatic stress disorder. Journal of Gender Specific Medicine. 2002;5:34-40. [pmid: 11859685].
Brewin CR. Remembering and forgetting. Friedman MJ, Keane TM, Resick PA, editors. Handbook of PTSD: Science and practice. 2007:116-134. New York. Guilford Press.
Brewin CR, Andrews B, Valentine JD. Meta-analysis of risk factors for posttraumatic stress disorder in trauma-exposed adults. Journal of Consulting and Clinical Psychology. 2000;68:748-766. [pmid: 11068961].
Bride BE. Prevalence of secondary traumatic stress among social workers. Social Work. 2007;52:63-70. [pmid: 17388084].
Briere J. 1995. Trauma symptom inventory professional manual. Odessa, FL. Psychological Assessment Resources.
Briere J. 1996. Therapy for adults molested as children: Beyond survival. 2nd ed. New York. Springer Pub.
Briere J. 1996. Trauma symptom checklist for children professional manual. Odessa, FL. Psychological Assessment Resources.
Briere J. 1997. Psychological assessment of adult posttraumatic states. 1st ed. Washington, DC. American Psychological Association.
Briere J, Scott C. Central issues in trauma treatment. Principles of trauma therapy: A guide to symptoms, evaluation, and treatment. 2006:67-85. Thousand Oaks, CA. Sage Publications.
Briere J, Scott C. 2006. Principles of trauma therapy: A guide to symptoms, evaluation, and treatment. Thousand Oaks, CA. Sage Publications.
Briere J, Scott C. 2012. Principles of trauma therapy: A guide to symptoms, evaluation, and treatment. 2nd ed. Thousand Oaks, CA. Sage Publications.
Bronfenbrenner U. 1979. The ecology of human development: Experiments by nature and design. Cambridge, MA. Harvard University Press.
Bronfenbrenner U, Ceci SJ. Nature–nurture reconceptualized in developmental perspective: A bioecological model. Psychological Review. 1994;101:568-586. [pmid: 7984707].
Brown LS. Feminist therapy. Lebow JL, editor. Twenty-first century psychotherapies: Contemporary approaches to theory and practice. 2008:277-306. Hoboken, NJ. John Wiley & Sons, Inc.
Brown PJ, Read JP, Kahler CW. Comorbid posttraumatic stress disorder and substance use disorders: Treatment outcomes and the role of coping. Ouimette P, Brown PJ, editors. Trauma and substance abuse: Causes, consequences, and treatment of comorbid disorders. 2003:171-188. Washington, DC. American Psychological Association.
Bryant RA, Harvey AG. 2000. Acute stress disorder: A handbook of theory, assessment, and treatment. 1st ed. Washington, DC. American Psychological Association.
Bryant RA, Harvey AG. Gender differences in the relationship between acute stress disorder and posttraumatic stress disorder following motor vehicle accidents. Australian and New Zealand Journal of Psychiatry. 2003;37:226-229. [pmid: 12656964].
Burke PA, Carruth B, Prichard D. Counselor self-care in work with traumatized addicted people. Carruth B, editor. Psychological trauma and addiction treatment. 2006:283-302. New York. Haworth Press.
Cahill SP, Rothbaum BO, Resick PA, Follette VM. Cognitive-behavioral therapy for adults. Foa EB, Keane TM, Friedman MJ, Cohen JA, editors. Effective treatments for PTSD: Practice guidelines from the International Society for Traumatic Stress Studies. 2nd ed. 2009:139-222. New York. Guilford Press.
Caldwell BA, Redeker N. Sleep and trauma: An overview. Issues in Mental Health Nursing. 2005;26:721-738. [pmid: 16126648].
Campbell-Sills L, Stein MB. Psychometric analysis and refinement of the Connor-Davidson Resilience Scale (CD-RISC): Validation of a 10-item measure of resilience. Journal of Traumatic Stress. 2007;20:1019-1028. [pmid: 18157881].
Capezza NM, Najavits LM. Rates of trauma-informed counseling at substance abuse treatment facilities: Reports from over 10,000 programs. Psychiatric Services. 2012;63:390-394. [pmid: 22476307].
Cardena E, Koopman C, Classen C, Waelde LC, Spiegel D. Psychometric properties of the Stanford Acute Stress Reaction Questionnaire (SASRQ): a valid and reliable measure of acute stress. Journal of Traumatic Stress. 2000;13:719-734. [pmid: 11109242].
Carlson EB, Putnam FW. An update on the Dissociative Experiences Scale. Dissociation. 1993;6:16-27.
Carroll JFX, McGinley JJ. A screening form for identifying mental health problems in alcohol/other drug dependent persons. Alcoholism Treatment Quarterly. 2001;19:33-47.
Catalano S. 2012. Intimate partner violence in the US. Washington, DC. Bureau of Justice Statistics.
Catalano SM. 2004. Criminal victimization, 2003: National crime victimization survey. Washington, DC. Bureau of Justice Statistics.
Centers for Disease Control and Prevention. 2009. The social-ecological model: A framework for prevention. Retrieved on November 20, 2013, from: http://www.cdc.gov/violenceprevention/overview/social-ecologicalmodel.html.
Centers for Disease Control and Prevention. 2012. Publications by health outcome: Adverse childhood experiences (ACE) study. Atlanta, GA. Centers for Disease Control and Prevention.
Centers for Disease Control and Prevention. 2013. January. 18. Adverse Childhood Experiences (ACE) Study. Retrieved on August 14, 2013, from http://www.cdc.gov/ace/about.htm.
Center for Mental Health Services. 1996. Responding to the needs of people with serious and persistent mental illness in times of major disaster. (Rep No SMA 96-3077). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Mental Health Services, Division of Prevention, Traumatic Stress and Special Programs, Emergency Mental Health and Traumatic Stress Services Branch. 2003. Fact sheet. (Rep No KEN 95-0011). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Mental Health Services, Substance Abuse and Mental Health Services Administration. 2005. Roadmap to seclusion and restraint free mental health services. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1993. Improving treatment for drug-exposed infants. Treatment Improvement Protocol (TIP) Series 5. HHS Publication No. (SMA) 95-3057. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1993. Pregnant, substance-using women. Treatment Improvement Protocol (TIP) Series 2. HHS Publication No. (SMA) 93-1998. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1993. Screening for infectious diseases among substance abusers. Treatment Improvement Protocol (TIP) Series 6. HHS Publication No. (SMA) 95-3060. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1994. Simple screening instruments for outreach for alcohol and other drug abuse and infectious diseases. Treatment Improvement Protocol (TIP) Series 11. HHS Publication No. (SMA) 94-2094. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1995. Alcohol and other drug screening of hospitalized trauma patients. Treatment Improvement Protocol (TIP) Series 16. HHS Publication No. (SMA) 95-3041. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1995. Combining alcohol and other drug treatment with diversion for juveniles in the justice system. Treatment Improvement Protocol (TIP) Series 21. HHS Publication No. (SMA) 95-3051. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1995. Developing state outcomes monitoring systems for alcohol and other drug abuse treatment. Treatment Improvement Protocol (TIP) Series 14. HHS Publication No. (SMA) 95-3031. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1995. The role and current status of patient placement criteria in the treatment of substance use disorders. Treatment Improvement Protocol (TIP) Series 13. HHS Publication No. (SMA) 95-3021. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1995. The tuberculosis epidemic: Legal and ethical issues for alcohol and other drug abuse treatment providers. Treatment Improvement Protocol (TIP) Series 18. HHS Publication No. (SMA) 95-3047. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1996. Treatment drug courts: Integrating substance abuse treatment with legal case processing. Treatment Improvement Protocol (TIP) Series 23. HHS Publication No. (SMA) 96-3113. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1997. A guide to substance abuse services for primary care clinicians. Treatment Improvement Protocol (TIP) Series 24. HHS Publication No. (SMA) 97-3139. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1997. Substance abuse treatment and domestic violence. Treatment Improvement Protocol (TIP) Series 25. HHS Publication No. (SMA) 97-3163. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1998. Comprehensive case management for substance abuse treatment. Treatment Improvement Protocol (TIP) Series 27. HHS Publication No. (SMA) 98-3222. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1998. Continuity of offender treatment for substance use disorders from institution to community. Treatment Improvement Protocol (TIP) Series 30. HHS Publication No. (SMA) 98-3245. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1998. Naltrexone and alcoholism treatment. Treatment Improvement Protocol (TIP) Series 28. HHS Publication No. (SMA) 98-3206. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1998. Substance abuse among older adults. Treatment Improvement Protocol (TIP) Series 26. HHS Publication No. (SMA) 98-3179. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1998. Substance use disorder treatment for people with physical and cognitive disabilities. Treatment Improvement Protocol (TIP) Series 29. HHS Publication No. (SMA) 98-3249. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1999. Brief interventions and brief therapies for substance abuse. Treatment Improvement Protocol (TIP) Series 34. HHS Publication No. (SMA) 99-3353. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1999. Enhancing motivation for change in substance abuse treatment. Treatment Improvement Protocol (TIP) Series 35. HHS Publication No. (SMA) 99-3354. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1999. Screening and assessing adolescents for substance use disorders. Treatment Improvement Protocol (TIP) Series 31. HHS Publication No. (SMA) 99-3282. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1999. Treatment of adolescents with substance use disorders. Treatment Improvement Protocol (TIP) Series 32. HHS Publication No. (SMA) 99-3283. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1999. Treatment for stimulant use disorders. Treatment Improvement Protocol (TIP) Series 33. HHS Publication No. (SMA) 99-3296. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2000. Integrating substance abuse treatment and vocational services. Treatment Improvement Protocol (TIP) Series 38. HHS Publication No. (SMA) 00-3470. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2000. Substance abuse treatment for persons with child abuse and neglect issues. Treatment Improvement Protocol (TIP) Series 36. HHS Publication No. (SMA) 00-3357. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2000. Substance abuse treatment for persons with HIV/AIDS. Treatment Improvement Protocol (TIP) Series 37. HHS Publication No. (SMA) 00-3459. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2004. Clinical guidelines for the use of buprenorphine in the treatment of opioid addiction. Treatment Improvement Protocol (TIP) Series 40. HHS Publication No. (SMA) 04-3939. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2004. Substance abuse treatment and family therapy. Treatment Improvement Protocol (TIP) Series 39. HHS Publication No. (SMA) 04-3957. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2005. Medication-assisted treatment for opioid addiction. Treatment Improvement Protocol (TIP) Series 43. HHS Publication No. SMA 05-4048. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2005. Substance abuse treatment for adults in the criminal justice system. Treatment Improvement Protocol (TIP) Series 44. HHS Publication No. (SMA) 05-4056. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2005. Substance abuse treatment for persons with co-occurring disorders. Treatment Improvement Protocol (TIP) Series 42. HHS Publication No. SMA 05-3992. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2005. Substance abuse treatment: Group therapy. Treatment Improvement Protocol (TIP) Series 41. HHS Publication No. SMA 05-4056. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2006. Detoxification and substance abuse treatment. Treatment Improvement Protocol (TIP) Series 45. HHS Publication No. SMA 06-4131. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2006. Substance abuse: Administrative issues in intensive outpatient treatment. Treatment Improvement Protocol (TIP) Series 46. HHS Publication No. SMA 06-4151. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2006. Substance abuse: Clinical issues in intensive outpatient treatment. Treatment Improvement Protocol (TIP) Series 47. HHS Publication No. SMA 06-4182. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2008. Managing depressive symptoms in substance abuse clients during early recovery. Treatment Improvement Protocol (TIP) Series 48. HHS Publication No. SMA 08-4353. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2009. Addressing suicidal thoughts and behaviors in substance abuse treatment. Treatment Improvement Protocol (TIP) Series 50. HHS Publication No. SMA 09-4381. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2009. Clinical supervision and the professional development of the substance abuse counselor. Treatment Improvement Protocol (TIP) Series 52. HHS Publication No. SMA 09-4435. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2009. Incorporating alcohol pharmacotherapies into medical practice. Treatment Improvement Protocol (TIP) Series 49. HHS Publication No. SMA 09-4380. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2009. Substance abuse treatment: Addressing the specific needs of women. Treatment Improvement Protocol (TIP) Series 51. HHS Publication No. SMA 09-4426. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2009. What are peer recovery support services?. HHS Publication No. SMA 09-4454. Rockville, MD. Substance Abuse and Mental Health Services Administration, U.S. Department of Health and Human Services.
Chambless DL, Hollon SD. Defining empirically supported therapies. Journal of Consulting and Clinical Psychology. 1998;66:7-18. [pmid: 9489259].
Chilcoat HD, Breslau N. Posttraumatic stress disorder and drug disorders: Testing causal pathways. Archives of General Psychiatry. 1998;55:913-917. [pmid: 9783562].
Christensen RC, Hodgkins CC, Garces LK, Estlund KL, Miller MD, Touchton R. Homeless, mentally ill and addicted: The need for abuse and trauma services. Journal of Health Care for the Poor and Underserved. 2005;16:615-621. [pmid: 16311487].
Claes L, Vandereycken W. Is there a link between traumatic experiences and self-injurious behaviours in eating-disordered patients?. Eating Disorders. 2007;15:305-315. [pmid: 17710568].
Claes L, Vandereycken W, Vertommen H. Self-care versus self-harm: Piercing, tattooing, and self-injuring in eating disorders. European Eating Disorders Review. 2005;13:11-18.
Clark C, Fearday FE. 2003. Triad women’s project: Group facilitator’s manual. Tampa, FL. Louis de la Parte Florida Mental Health Institute, University of South Florida.
Cloitre M, Koenen KC, Cohen LR, Han H. Skills training in affective and interpersonal regulation followed by exposure: A phase-based treatment for PTSD related to childhood abuse. Journal of Consulting and Clinical Psychology. 2002;70:1067-1074. [pmid: 12362957].
Coffey SF, Dansky BS, Brady KT. Exposure-based, trauma focused therapy for comorbid posttraumatic stress disorder-substance use disorder. Ouimette P, Brown PJ, editors. Trauma and substance abuse: Causes, consequences, and treatment of comorbid disorders. 2003:127-146. Washington, DC. American Psychological Association.
Coffey SF, Schumacher JA, Brady KT, Dansky BS. 2003. Reductions in trauma symptomalogy during acute and protracted alcohol and cocaine abstinence. Symposium conducted at the Annual Meeting of the International Society for Traumatic Stress Studies. Chicago, IL.
Coffey SF, Schumacher JA, Brimo ML, Brady KT. Exposure therapy for substance abusers with PTSD: Translating research to practice. Behavior Modification. 2005;29:10-38. [pmid: 15557477].
Connor KM, Davidson JRT. Development of a new resilience scale: The Connor-Davidson Resilience Scale (CD-RISC). Depression and Anxiety. 2003;18:76-82. [pmid: 12964174].
Connors GJ, Donovan DM, DiClemente CC. 2001. Substance abuse treatment and the stages of change selecting and planning interventions. New York. Guilford Press.
Cottler LB, Nishith P, Compton WM. Gender differences in risk factors for trauma exposure and post-traumatic stress disorder among inner-city drug abusers in and out of treatment. Comprehensive Psychiatry. 2001;42:111-117. [pmid: 11244146].
Courtois CA, Ford JD, editors. 2009. Treating complex traumatic stress disorders: An evidence-based guide. New York. Guilford Press.
Covington SS. 2003. Beyond trauma: A healing journey for women: Facilitator’s guide. Center City, MN. Hazelden.
Covington SS. 2008. Helping women recover: A program for treating addiction. Revised loose leaf ed. San Francisco. Jossey-Bass.
Cross TL, Bazron BJ, Dennis KW, Isaacs MR. Towards a culturally competent system of care: A monograph on effective services for minority children who are severely emotionally disturbed. 1989;1. Washington, DC. Georgetown University Child Development Center.
Danieli Y, Brom D, Sills J. Sharing knowledge and shared care. Journal of Aggression, Maltreatment & Trauma. 2005;10:775-790.
Daniels A, Grant E, Filson B, Powell I, Fricks L, Goodale L. 2010. Pillars of peer support: Transforming mental health systems of care through peer support services. Retrieved on November 21, 2013, from: http://www.pillarsofpeersupport.org/final%20%20PillarsofPeerSupportService%20Report.pdf.
Daniels AS, Tunner TP, Ashenden P, Bergeson S, Fricks L, Powell I. 2012. Pillars of peer support - III: Whole health peer support services. Retrieved on November 21, 2013, from: http://www.pillarsofpeersupport.org/P.O.PS2011.pdf.
Dass-Brailsford P, Myrick AC. Psychological trauma and substance abuse: The need for an integrated approach. Trauma, Violence, & Abuse. 2010;11:202-213.
Daoust JP, Renaud M, Bruyere B, Lemieux V, Fleury G, Najavits LM. 2012. Posttraumatic stress disorder and substance use disorder: Evaluation of the effectiveness of a specialized clinic for French-Canadians based in a teaching hospital. Retrieved on November 21, 2013, from: http://www.seekingsafety.org/3-03-06/studies.html.
Davidson JR, Book SW, Colket JT, Tupler LA, Roth S, David D, et al. Assessment of a new self-rating scale for post-traumatic stress disorder. Psychological Medicine. 1997;27:153-160. [pmid: 9122295].
De Bellis MD. Developmental traumatology: A contributory mechanism for alcohol and substance use disorders. Psychoneuroendocrinology. 2002;27:155-170. [pmid: 11750776].
de Fabrique N, Van Hasselt VB, Vecchi GM, Romano SJ. Common variables associated with the development of Stockholm syndrome: Some case examples. Victims & Offenders. 2007;2:91-98.
de Girolamo G. International perspectives on the treatment and prevention of posttraumatic stress disorder. Wilson JP, Beverley Raphael, editors. International handbook of traumatic stress syndrome. 1993:935-946. New York. Plenum Press.
dePanfilis D. 2006. Child neglect: A guide for prevention, assessment, and intervention. Washington, DC. U.S. Department of Health and Human Services, Administration for Children and Families, Administration on Children, Youth and Families Children’s Bureau, Office on Child Abuse and Neglect.
DeWolfe DJ. 2000. Training manual: For mental health and human service workers in major disasters. (Rep No ADM 90-538). Rockville, MD. Substance Abuse and Mental Health Services Administration.
Dillon JR. Internalized homophobia, attributions of blame, and psychological distress among lesbian, gay, and bisexual trauma victims. Dissertation Abstracts International: Section B: The Sciences & Engineering. 2001;62:2054.
Dom G, De WB, Hulstijn W, Sabbe B. Traumatic experiences and posttraumatic stress disorders: differences between treatment-seeking early- and late-onset alcoholic patients. Comprehensive Psychiatry. 2007;48:178-185. [pmid: 17292709].
Driessen M, Schulte S, Luedecke C, Schaefer I, Sutmann F, Ohlmeier M, et al. Trauma and PTSD in patients with alcohol, drug, or dual dependence: A multi-center study. Alcoholism: Clinical & Experimental Research. 2008;32:481-488.
Dube SR, Anda RF, Felitti VJ, Edwards VJ, Croft JB. Adverse childhood experiences and personal alcohol abuse as an adult. Addictive Behaviors. 2002;27:713-725. [pmid: 12201379].
Duckworth MP, Follette VM. 2011. Retraumatization: Assessment, treatment, and prevention. New York. Brunner-Routledge.
Ehlers A, Clark D. Early psychological interventions for adult survivors of trauma: A review. Biological Psychiatry. 2003;53:817-826. [pmid: 12725974].
El-Gabalawy R. 2012. Association between traumatic experiences and physical health conditions in a nationally representative sample. Retrieved on November 21, 2013, from: http://www.adaa.org/sites/default/files/El-Gabalawy%20331.pdf.
Ellis A, Harper RA. 1975. A new guide to rational living. Oxford, England. Prentice-Hall.
Elliott DE, Bjelajac P, Fallot RD, Markoff LS, Reed BG. Trauma-informed or trauma-denied: Principles and implementation of trauma-informed services for women. Journal of Community Psychology. 2005;33:461-477.
EMDR Network. 2012. A brief description of EMDR therapy. Retrieved on November 21, 2013, Retrieved on November 21from: http://www.emdrnetwork.org/description.html.
Falck RS, Wang J, Siegal HA, Carlson RG. The prevalence of psychiatric disorder among a community sample of crack cocaine users: An exploratory study with practical implications. Journal of Nervous and Mental Disease. 2004;192:503-507. [pmid: 15232321].
Falender CA, Shafranske EP. 2004. Clinical supervision: A competency-based approach. 1st ed. Washington, DC. American Psychological Association.
Fallot RD, Harris M. A trauma-informed approach to screening and assessment. Harris M, Fallot RD, editors. Using trauma theory to design service systems. 2001:23-31. San Francisco. Jossey-Bass.
Fallot RD, Harris M. The trauma recovery and empowerment model (TREM): Conceptual and practical issues in a group intervention for women. Community Mental Health Journal. 2002;38:475-485. [pmid: 12474935].
Fallot RD, Harris M. 2009. Creating cultures of trauma-informed care (CCTIC): A self-assessment and planning protocol. Washington, DC. Community Connections.
Falsetti SA, Resnick HS, Resnick PA, Kilpatrick D. The Modified PTSD Symptom Scale: A brief self-report measure of posttraumatic stress disorder. Behavior Therapist. 1993;16:161-162.
Farley M, Golding JM, Young G, Mulligan M, Minkoff JR. Trauma history and relapse probability among patients seeking substance abuse treatment. Journal of Substance Abuse Treatment. 2004;27:161-167. [pmid: 15450649].
Feder A, Charney D, Collins K. Neurobiology of resilience. Southwick SM, Litz BT, Charney D, Friedman MJ, editors. Resilience and mental health: Challenges across the lifespan. 2011:1-29. New York. Cambridge University Press.
Feldner MT, Monson CM, Friedman MJ. A critical analysis of approaches to targeted PTSD prevention: Current status and theoretically derived future directions. Behavior Modification. 2007;31:80-116. [pmid: 17179532].
Felitti VJ, Anda RF, Nordenberg D, Williamson DF, Spitz AM, Edwards V, et al. Relationship of childhood abuse and household dysfunction to many of the leading causes of death in adults: The Adverse Childhood Experiences (ACE) study. American Journal of Preventive Medicine. 1998;14:245-258. [pmid: 9635069].
Figley CR. Compassion fatigue: Toward a new understanding of the costs of caring. Stamm BH, editor. Secondary traumatic stress: Self-care issues for clinicians, researchers, and educators. 1995:3-28. Lutherville, MD. Sidran Press.
Figley CR. Origins of traumatology and prospects for the future, part i. Journal of Trauma Practice. 2002;1:17-32.
First MB, Spitzer RL, Gibbon M, Williams JBW. 2011. Structured clinical interview for DSM-IV-TR axis I disorders, research version, non-patient edition. New York. Biometrics Research, New York State Psychiatric Institute.
First MB, Spitzer RL, Gibbon M, Williams JBW. 2011. Structured clinical interview for DSM-IV-TR axis I disorders, research version, patient edition. New York. Biometrics Research, New York State Psychiatric Institute.
Foa EB, Dancu CV, Hembree EA, Jaycox LH, Meadows EA, Street GP. A comparison of exposure therapy, stress inoculation training, and their combination for reducing posttraumatic stress disorder in female assault victims. Journal of Consulting and Clinical Psychology. 1999;67:194-200. [pmid: 10224729].
Foa EB, Hembree EA, Rothbaum BO. 2007. Prolonged exposure therapy for PTSD: Emotional processing of traumatic experiences: Therapist guide. New York. Oxford University Press.
Foa EB, Keane TM, Friedman MJ, Cohen JA. Introduction. Foa EB, Keane TM, Friedman MJ, Cohen JA, editors. Effective treatments for PTSD: Practice guidelines from the International Society for Traumatic Stress Studies. 2nd ed. 2009:1-20. New York. Guilford Press.
Foa EB, Rothbaum BO, Riggs DS, Murdock TB. Treatment of posttraumatic stress disorder in rape victims: A comparison between cognitive-behavioral procedures and counseling. Journal of Consulting & Clinical Psychology. 1991;59:715-723. [pmid: 1955605].
Foa EB, Stein DJ, McFarlane AC. Symptomatology and psychopathology of mental health problems after disaster. Journal of Clinical Psychiatry. Supplement 2. 2006;67:15-25. [pmid: 16602811].
Ford JD, Fournier D. Psychological trauma and post-traumatic stress disorder among women in community mental health aftercare following psychiatric intensive care. Journal of Psychiatric Intensive Care. 2007;3:27-34.
Ford JD, Russo E. Trauma-focused, present-centered, emotional self-regulation approach to integrated treatment for posttraumatic stress and addiction: Trauma adaptive recovery group education and therapy (TARGET). American Journal of Psychotherapy. 2006;60:335-355. [pmid: 17340945].
Foy DW, Ruzek JI, Glynn SM, Riney SJ, Gusman FD. Trauma focus group therapy for combat-related PTSD: An update. Journal of Clinical Psychology. 2002;58:907-918. [pmid: 12115714].
Frank B, Dewart T, Schmeidler J, Demirjian A. The impact of 9/11 on New York City’s substance abuse treatment programs: A study of program administrators. Journal of Addictive Diseases. 2006;25:5-14. [pmid: 16597568].
Frankl VE. 1992. Man’s search for meaning: An introduction to logotherapy. 4th ed. Boston. Beacon Press.
Friborg O, Hjemdal O, Rosenvinge JH, Martinussen M. A new rating scale for adult resilience: What are the central protective resources behind healthy adjustment?. International Journal of Methods in Psychiatric Research. 2003;12:65-76. [pmid: 12830300].
Friedman MJ. Posttraumatic stress disorder among military returnees from Afghanistan and Iraq. American Journal of Psychiatry. 2006;163:586-593. [pmid: 16585431].
Frisman L, Ford J, Lin HJ, Mallon S, Chang R. Outcomes of trauma treatment using the TARGET model. Journal of Groups in Addiction and Recovery. 2008;3:285-303.
Frueh BC, Knapp RG, Cusack KJ, Grubaugh AL, Sauvageot JA, Cousins VC, et al. Patients’ reports of traumatic or harmful experiences within the psychiatric setting. Psychiatric Services. 2005;56:1123-1133. [pmid: 16148328].
Galea S, Ahern J, Resnick Kilpatrick D, Bucuvalas M, Gold J, et al. Psychological sequelae of the September 11 terrorist attacks in New York City. New England Journal of Medicine. 2002;346:982-987. [pmid: 11919308].
Gentilello LM, Ebel BE, Wickizer TM, Salkever DS, Rivara FP. Alcohol interventions for trauma patients treated in emergency departments and hospitals: A cost benefit analysis. Annals of Surgery. 2005;241:541-550. [pmid: 15798453].
Gentilello LM, Villaveces A, Ries RR, Nason KS, Daranciang E, Donovan DM, et al. Detection of acute alcohol intoxication and chronic alcohol dependence by trauma center staff. Journal of Trauma. 1999;47:1131-1135. [pmid: 10608546].
Gill DA, Picou JS. The day the water died: Cultural impacts of the Exxon Valdez oil spill. Picou JS, editor. The Exxon Valdez disaster: Readings on a modern social problem. 1997:167-187. Dubuque, IA. Indo American Books.
Gone JP. A community-based treatment for Native American historical trauma: Prospects for evidence-based practice. Journal of Consulting and Clinical Psychology. 2009;77:751-762. [pmid: 19634967].
Goodell J. 2003. Who’s a hero now?. Retrieved on November 21, 2013 from: http://www.nytimes.com/2003/07/27/magazine/who-s-a-hero-now.html.
Grant BF, Stinson FS, Dawson DA, Chou SP, Dufour MC, Compton W, et al. Prevalence and co-occurrence of substance use disorders and independent mood and anxiety disorders: Results from the National Epidemiologic Survey on Alcohol and Related Conditions. Archives of General Psychiatry. 2004;61:807-816. [pmid: 15289279].
Green BL. Trauma History Questionnaire. Stamm BH, editor. Measurement of stress, trauma, and adaptation. 1996:366-369. Lutherville, MD. Sidran Press.
Green Cross Academy of Traumatology. 2007. Standards of traumatology practice revised. Retrieved on November 18, 2013, from: http://www.greencross.org/index.php?option=com_content&view=article&id=183&Itemid=123.
Green Cross Academy of Traumatology. 2010. Standards of self care. Retrieved on November 21, 2013, from: http://www.greencross.org/index.php?option=com_content&view=article&id=184&Itemid=124.
Green JG, McLaughlin KA, Berglund PA, Gruber MJ, Sampson NA, Zaslavsky AM, et al. Childhood adversities and adult psychiatric disorders in the National Comorbidity Survey Replication I: Associations with first onset of DSM-IV disorders. Archives of General Psychiatry. 2010;67:113-123. [pmid: 20124111].
Greene LR, Meisler AW, Pilkey D, Alexander G, Cardella LA, Sirois BC, et al. Psychological work with groups in the Veterans Administration. DeLucia-Waack JL, Gerrity DA, Kalodner CR, Riva MT, editors. Handbook of group counseling and psychotherapy. 2004:322-337. Thousand Oaks, CA. Sage Publications.
Grossman D. 1995. On killing: The psychological cost of learning to kill in war and society. 1st ed. Boston. Little Brown.
Guarino K, Soares P, Konnath K, Clervil R, Bassuk E. 2009. Trauma-informed organizational toolkit. Rockville, MD. Center for Mental Health Services, Substance Abuse and Mental Health Services Administration and the Daniels Fund, the National Child Traumatic Stress Network, and the W.K. Kellogg Foundation.
Gutheil TG, Brodsky A. 2008. Preventing boundary violations in clinical practice. New York. Guilford Press.
Habukawa M, Maeda M, Uchimura N. Sleep disturbances in posttraumatic stress disorder. Sher L, Vilens A, editors. Neurobiology of post-traumatic stress disorder. 2010:119-135. Hauppage, NY. Nova Science Publishers, Inc.
Hamblen J. 2001. PTSD in children and adolescents, a National Center for PTSD fact sheet. Washington, DC. National Center for PTSD.
Harned MS, Najavits LM, Weiss RD. Self-harm and suicidal behavior in women with comorbid PTSD and substance dependence. American Journal of Addiction. 2006;15:392-395.
Harris M, Fallot RD. Envisioning a trauma-informed service system: A vital paradigm shift. Harris M, Fallot RD, editors. Using trauma theory to design service systems. 2001:3-22. San Francisco. Jossey-Bass.
Harris M, Fallot RD. Trauma-informed inpatient services. Harris M, Fallot RD, editors. Using trauma theory to design service systems. 2001:33-46. San Francisco. Jossey-Bass.
Harris M, Fallot RD. 2001. Using trauma theory to design service systems: New directions for mental health services. San Francisco. Jossey-Bass.
Harris M. The Community Connections Trauma Work Group. 1998. Trauma recovery and empowerment: A clinician’s guide for working with women in groups. New York. Simon & Schuster.
Hayes SC. Acceptance and commitment therapy and the new behavior therapies: Mindfulness, acceptance, and relationship. Hayes SC, Follette VM, Linehan MM, editors. Mindfulness and acceptance: Expanding the cognitive-behavioral tradition. 2004:1-29. New York. Guilford Press.
Heim C, Mletzko T, Purselle D, Musselman DL, Nemeroff CB. The dexamethasone/corticotropin-releasing factor test in men with major depression: Role of childhood trauma. Biological Psychiatry. 2008;63:398-405. [pmid: 17825799].
Heim C, Newport DJ, Mletzko T, Miller AH, Nemeroff CB. The link between childhood trauma and depression: Insights from HPA axis studies in humans. Psychoneuroendocrinology. 2008;33:693-710. [pmid: 18602762].
Herman JL. 1992. Trauma and recovery. New York. Basic Books.
Herman JL. 1997. Trauma and recovery. Rev ed. New York. Basic Books.
Hoge MA, Morris JA, Daniels AS, Stuart GW, Huey LY, Adams N. 2007. An action plan for behavioral health workforce development: A framework for discussion. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Hooper LM, Stockton P, Krupnick JL, Green BL. Development, use, and psycho-metric properties of the Trauma History Questionnaire. Journal of Loss and Trauma. 2011;16:258-283.
Hopper EK, Bassuk EL, Olivet J. Shelter from the storm: Trauma-informed care in homelessness services settings. The Open Health Services and Policy Journal. 2010;3:80-100.
Horowitz M, Wilner N, Alvarez W. Impact of Event Scale: A measure of subjective stress. Psychosomatic Medicine. 1979;41:209-218. [pmid: 472086].
Huckshorn K. 2009. Transforming cultures of care toward recovery oriented services: Guidelines toward creating a trauma informed system of care: Trauma informed care (TIC) planning guidelines for use in developing an organizational action plan. Austin, TX. Texas Network of Youth Services.
Hui CH, Triandis HC. Individualism–collectivism: A study of cross-cultural researchers. Journal of Cross-Cultural Psychology. 1986;17:225-248.
Huriwai T. Re-enculturation: Culturally congruent interventions for Maori with alcohol-and drug-use-associated problems in New Zealand. Substance Use and Misuse. 2002;37:1259-1268. [pmid: 12180565].
Hutton D. Patterns of psychosocial coping and adaptation among riverbank erosion-induced displacees in Bangladesh: Implications for development programming. Prehospital and Disaster Medicine. 2000;15:S99.
Institute of Medicine. 2008. Treatment of posttraumatic stress disorder: An assessment of the evidence. Washington, DC. The National Academies Press.
Institute of Medicine & National Research Council. 2007. PTSD compensation and military service. Washington, DC. The National Academies.
Institute of Medicine, Committee on Prevention of Mental Disorders and Substance Abuse Among Children, National Research Council (U.S.), et al. O’Connell ME, Boat TF, Warner KE. 2009. Preventing mental, emotional, and behavioral disorders among young people: Progress and possibilities. Washington, DC. National Academies Press.
Jackson C, Nissenson K, Cloitre M. Cognitive-behavioral therapy. Courtois CA, editor. Treating complex traumatic stress disorders: An evidence-based guide. 2009:243-263. New York. Guilford Press.
Jainchill N, Hawke J, Yagelka J. Gender, psychopathology, and patterns of homelessness among clients in shelter-based TCs. American Journal of Drug and Alcohol Abuse. 2000;26:553-567. [pmid: 11097192].
Janoff-Bulman R. 1992. Shattered assumptions: Towards a new psychology of trauma. New York. Free Press.
Jennings A. 2004. Models for developing trauma-informed behavioral health systems and trauma-specific services. Retrieved on November 21, 2013, from: http://www.theannainstitute.org/MDT.pdf.
Jennings A. 2007. Blueprint for action: Building trauma-informed mental health service systems: State accomplishments, activities and resources. Retrieved on November 21, 2013, from: http://www.theannainstitute.org/2007%202008%20Blueprint%20By%20Criteria%202%2015%2008.pdf.
Jennings A. 2007. Criteria for building a trauma-informed mental health service system. Adapted from “Developing Trauma-Informed Behavioral Health Systems. Retrieved on November 21, 2013, from: http://www.theannainstitute.org/CBTIMHSS.pdf.
Jennings A. 2009. Models for developing trauma-informed behavioral health systems and trauma-specific services: 2008 update. Retrieved on November 21, 2013, from: http://www.theannainstitute.org/Models%20for%20Developing%20Traums-Report%201-09-09%20_FINAL_.pdf.
Kabat-Zinn J. 1994. Wherever you go, there you are: Mindfulness meditation in everyday life. 1st ed. New York. Hyperion.
Kabat-Zinn J. University of Massachusetts Medical Center/Worcester, & Stress, R. C. 1990. Full catastrophe living: Using the wisdom of your body and mind to face stress, pain, and illness. New York. Delacorte Press.
Karlin BE, Ruzek JI, Chard KM, Eftekhari A, Monson CM, Hembree EA, et al. Dissemination of evidence-based psychological treatments for posttraumatic stress disorder in the Veterans Health Administration. Journal of Traumatic Stress. 2010;23:663-673. [pmid: 21171126].
Karon BP, Widener AJ. Repressed memories and World War II: Lest we forget!. Professional Psychology: Research and Practice. 1997;28:338-340.
Keane TM, Brief DJ, Pratt EM, Miller MW. Assessment of PTSD and its comorbidities in adults. Friedman MJ, Keane TM, Resick PA, editors. Handbook of PTSD: Science and practice. 2007:279-305. New York. Guilford Press.
Keane TM, Fairbank JA, Caddell JM, Zimering RT, Taylor KL, Mora CA. Clinical evaluation of a measure to assess combat exposure. Psychological Assessment. 1989;1:53-55.
Keane TM, Piwowarczyk LA. Trauma, terror, and fear: Mental health professionals respond to the impact of 9/11–an overview. Schein LA, Spitz HI, Burlingame GM, Muskin PR, editors. Psychological effects of catastrophic disasters: Group approaches to treatment. 2006:3-16. New York. Haworth Press.
Kelly DC, Howe-Barksdale S, Gitelson D. 2011. Treating young veterans: Promoting resilience through practice and advocacy. New York. Springer Publishing.
Kessler RC, Chiu WT, Demler O, Merikangas KR, Walters EE. Prevalence, severity, and comorbidity of 12-month DSM-IV disorders in the National Comorbidity Survey replication. Archives of General Psychiatry. 2005;62:617-627. [pmid: 15939839].
Kessler RC, Sonnega A, Bromet E, Hughes M, Nelson CB. Posttraumatic stress disorder in the National Comorbidity Survey. Archives of General Psychiatry. 1995;52:1048-1060. [pmid: 7492257].
Kessler RC, Sonnega A, Bromet E, Hughes M, Nelson CB, Breslau NN. Epidemiological risk factors for trauma and PTSD. Yehuda R, editor. Risk factors for PTSD. 1999:23-59. Washington, DC. American Psychiatric Press.
Khantzian EJ. The self-medication hypothesis of addictive disorders: focus on heroin and cocaine dependence. American Journal of Psychiatry. 1985;142:1259-1264. [pmid: 3904487].
Kilpatrick DG, Veronen LJ, Resick PA. Psychological sequelae to rape: Assessment and treatment strategies. Doleys DM, Meredith RL, Ciminero AR, editors. Behavioral medicine: assessment and treatment strategies. 1982:473-497. New York. Plenum.
Kimerling R, Ouimette P, Weitlauf JC. Gender issues in PTSD. Friedman MJ, Keane TM, Resick PA, editors. Handbook of PTSD: Science and practice. 2007:207-228. New York. Guilford Press.
Kirmayer LJ. Confusion of the senses: Implications of ethnocultural variations in somatoform and dissociative disorders for PTSD. Marsella AJ, Friedman MJ, editors. Ethnocultural aspects of posttraumatic stress disorder: Issues, research, and clinical applications. 1996:131-163. Washington, DC. American Psychological Association.
Klinic Community Health Centre. 2008. Trauma-informed: The trauma toolkit. Winnipeg, Manitoba. Klinic Community Health Centre.
Koenen KC, Stellman SD, Sommer JF Jr, Stellman JM. Persisting posttraumatic stress disorder symptoms and their relationship to functioning in Vietnam veterans: A 14-year follow-up. Journal of Traumatic Stress. 2008;21:49-57. [pmid: 18302174].
Koenen KC, Stellman JM, Stellman SD, Sommer JF Jr. Risk factors for course of posttraumatic stress disorder among Vietnam veterans: A 14-year follow-up of American Legionnaires. Journal of Consulting & Clinical Psychology. 2003;71:980-986. [pmid: 14622073].
Kozarić-Kovačić D, Ljubin T, Grappe M. Comorbidity of posttraumatic stress disorder and alcohol dependence in displaced persons. Croatian Medical Journal. 2000;41:173-178. [pmid: 10853047].
Kramer TL, Green BL. Post-traumatic stress disorder: A historical context and evolution. Halpern DF, editor. States of mind: American and post-Soviet perspectives on contemporary issues in psychology. 1997:215-237. New York. Oxford University Press.
Kress VE, Hoffman RM. Non-suicidal self-injury and motivational interviewing: Enhancing readiness for change. Journal of Mental Health Counseling. 2008;30:311-329.
Kubany ES, Haynes SN, Leisen MB, Owens JA, Kaplan AS, Watson SB, et al. Development and preliminary validation of a brief broad-spectrum measure of trauma exposure: The Traumatic Life Events Questionnaire. Psychological Assessment. 2000;12:210-224. [pmid: 10887767].
Kuhn JH, Nakashima J. 2011. Community homelessness assessment, local education and networking croup (CHALENG) for veterans: The seventeenth annual progress report. Retrieved on November 21, 2013, from: http://www.va.gov/HOMELESS/docs/chaleng/CHALENG_Report_Seventeenth_Annual.pdf.
Lasiuk GC, Hegadoren KM. Posttraumatic stress disorder part I: Historical development of the concept. Perspectives in Psychiatric Care. 2006;42:13-20. [pmid: 16480413].
Lavretsky H, Siddarth P, Irwin MR. Improving depression and enhancing resilience in family dementia caregivers: A pilot randomized placebo-controlled trial of escitalopram. The American Journal of Geriatric Psychiatry. 2010;18:154-162. [pmid: 20104071].
Lester KM, Milby JB, Schumacher JE, Vuchinich R, Person S, Clay OJ. Impact of behavioral contingency management intervention on coping behaviors and PTSD symptom reduction in cocaine-addicted homeless. Journal of Traumatic Stress. 2007;20:565-575. [pmid: 17721968].
Linehan MM. Dialectical behavior therapy for treatment of borderline personality disorder: Implications for the treatment of substance abuse. Onken LS, Blaine JD, Boren JJ, editors. Behavioral treatments for drug abuse and dependence. 1993:201-216. Rockville, MD. National Institute on Drug Abuse.
Litz BT, Gray MJ. Early intervention for mass violence: What is the evidence? What should be done?. Cognitive and Behavioral Practice. 2002;9:266-272.
Litz BT, Miller M, Ruef A, McTeague L. 2002. Exposure to trauma in adults. Antony M, Barlow D, editors. Handbook of assessment and treatment planning for psychological disorders. New York. Guilford Press.
Liu D, Diorio J, Day JC, Francis DD, Meaney MJ. Maternal care, hippocampal synaptogenesis and cognitive development in rats. Nature Neuroscience. 2000;3:799-806.
Mahalik JR. Cognitive therapy for men. Brooks GR, Good GE, editors. The new handbook of psychotherapy and counseling with men: A comprehensive guide to settings, problems, and treatment approaches. 2001:544-564. San Francisco. Jossey-Bass.
Malta LS, Levitt JT, Martin A, Davis L, Cloitre M. Correlates of functional impairment in treatment-seeking survivors of mass terrorism. Behavior Therapy. 2009;40:39-49. [pmid: 19187815].
Marlatt GA, Donovan DM, editors. 2005. Relapse prevention: Maintenance strategies in the treatment of addictive behaviors. 2nd ed. New York. Guilford Press.
Martino S, Canning-Ball M, Carroll KM, Rounsaville BJ. A criterion-based stepwise approach for training counselors in motivational interviewing. Journal of Substance Abuse Treatment. 2011;40:357-365. [pmid: 21316183].
Maschi T, Brown D. Professional self-care and prevention of secondary trauma. Helping bereaved children: A handbook for practitioners. 3rd ed. 2010:345-373. New York. Guilford Press.
McCaig LF, Burt CW. 2005. National Hospital Ambulatory Medical Care Survey: 2003 emergency department summary. Hyattsville, MD. National Center for Health Statistics.
McCann L, Pearlman LA. Vicarious traumatization: A framework for understanding the psychological effects of working with victims. Journal of Traumatic Stress. 1990;3:1.
McGarrigle T, Walsh CA. Mindfulness, self-care, and wellness in social work: Effects of contemplative training. Journal of Religion & Spirituality in Social Work: Social Thought. 2011;30:212-233.
McGovern MP, Lambert-Harris C, Alterman AI, Xie H, Meier A. A randomized controlled trial comparing integrated cognitive behavioral therapy versus individual addiction counseling for co-occurring substance use and posttraumatic stress disorders. Journal of Dual Diagnosis. 2011;7:207-227. [pmid: 22383864].
McLeod J. 1997. Narrative and psychotherapy. London. Sage Publications.
McNally RJ. 2003. Remembering trauma. Cambridge, MA. Belknap Press of Harvard University Press.
McNally RJ. Debunking myths about trauma and memory. The Canadian Journal of Psychiatry/La Revue Canadienne de Psychiatrie. 2005;50:817-822.
McNally RJ, Bryant RA, Ehlers A. Does early psychological intervention promote recovery from posttraumatic stress?. Psychological Science in the Public Interest. 2003;4:45-79.
McNamara C, Schumacher JE, Milby JB, Wallace D, Usdan S. Prevalence of nonpsychotic mental disorders does not affect treatment outcome in a homeless cocaine-dependent sample. American Journal of Drug and Alcohol Abuse. 2001;27:91-106. [pmid: 11373038].
Mead S. 2008. Intentional peer support: An alternative approach. Plainfield, NH. Shery Mead Consulting.
Meaney MJ, Brake W, Gratton A. Environmental regulation of the development of mesolimbic dopamine systems: A neurobiological mechanism for vulnerability to drug abuse?. Psychoneuroendocrinology. 2002;27:127-138. [pmid: 11750774].
Meichenbaum D. 1994. A clinical handbook/practical therapist manual for assessing and treating adults with post-traumatic stress disorder (PTSD). Waterloo, Ontario. Institute Press.
Meichenbaum D. Stress inoculation training for coping with stressors. The Clinical Psychologist. 1996;49:4-7.
Meichenbaum D. Stress inoculation training: A preventative and treatment approach. Principles and practice of stress management. 3rd ed. 2007:497-516. New York. Guilford Press.
Meichenbaum DH, Deffenbacher JL. Stress inoculation training. Counseling Psychologist. 1988;16:69-90.
Melnick SM, Bassuk EL. 2000. Identifying and responding to violence among poor and homeless women. Nashville, TN. National Healthcare for the Homeless Council.
Meltzer-Brody S, Churchill E, Davidson JRT. Derivation of the SPAN, a brief diagnostic screening test for post-traumatic stress disorder. Psychiatry Research. 1999;88:63-70. [pmid: 10641587].
Mental Health America Centers for Technical Assistance. 2012. Trauma recovery and empowerment model (TREM). Alexandria, VA. Mental Health America Centers for Technical Assistance.
Miller D, Guidry L. 2001. Addictions and trauma recovery: Healing the body, mind, and spirit. New York. WW Norton and Co.
Miller KE, Weine SM, Ramic A, Brkic N, Bjedic ZD, Smajkic A, et al. The relative contribution of war experiences and exile-related stressors to levels of psychological distress among Bosnian refugees. Journal of Traumatic Stress. 2002;15:377-387. [pmid: 12392225].
Miller NA, Najavits LM. Creating trauma-informed correctional care: A balance of goals and environment. European Journal of Psychotraumatology. 2012;3:17246.
Miller WR, Rollnick S. 2002. Motivational interviewing: Preparing people for change. 2nd ed. New York. Guilford Press.
Mills KL, Teesson M, Back SE, Brady KT, Baker AL, Hopwood S, et al. Integrated exposure-based therapy for co-occurring posttraumatic stress disorder and substance dependence: A randomized controlled trial. JAMA. 2012;308:690-699. [pmid: 22893166].
Mills KL, Teesson M, Ross J, Peters L. Trauma, PTSD, and substance use disorders: Findings from the Australian National Survey of Mental Health and Well-Being. American Journal of Psychiatry. 2006;163:652-658. [pmid: 16585440].
Mitchell JT, Everly GS Jr. 2001. Critical Incident Stress Debriefing: An operations manual for CISD, defusing and other group crisis intervention services. 3rd ed. Ellicott City, MD. Chevron Publishing Corporation.
Mollick L, Spett M. 2002. Cloitre: Why exposure fails with most PTSD patients. Retrieved on November 21, 2013, from: http://www.nj-act.org/cloitre.html.
Monson CM, Schnurr PP, Resick PA, Friedman MJ, Young-Xu Y, Stevens SP. Cognitive processing therapy for veterans with military-related posttraumatic stress disorder. Journal of Consulting and Clinical Psychology. 2006;74:898-907. [pmid: 17032094].
Moore BA, Kennedy CH. 2011. Wheels down: Adjusting to life after deployment. 1st ed. Washington, DC. American Psychological Association.
Morrissey JP, Jackson EW, Ellis AR, Amaro H, Brown VB, Najavits LM. Twelve-month outcomes of trauma-informed interventions for women with co-occurring disorders. Psychiatric Services. 2005;56:1213-1222. [pmid: 16215186].
Moul DE, Hall M, Pilkonis PA, Buysse DJ. Self-report measures of insomnia in adults: Rationales, choices, and needs. Sleep Medicine Review. 2004;8:177-198.
Mueser KT, Salyers MP, Rosenberg SD, Goodman LA, Essock SM, Osher FC, et al. Interpersonal trauma and posttraumatic stress disorder in patients with severe mental illness: Demographic, clinical, and health correlates. Schizophrenia Bulletin. 2004;30:45-57. [pmid: 15176761].
Myers DG, Wee DF. Strategies for managing disaster mental health worker stress. Figley CR, editor. Treating compassion fatigue. 2002:181-211. New York. Brunner-Routledge.
Najavits LM. 2002. Seeking safety: A treatment manual for PTSD and substance abuse. New York. Guilford Press.
Najavits LM. 2002. Seeking safety: Psychotherapy for PTSD and substance abuse. Retrieved on November 21, 2013, from: http://www.seekingsafety.org/.
Najavits LM. Assessment of trauma, PTSD, and substance use disorder: A practical guide. Wilson JP, Keane T, editors. Assessing psychological trauma and PTSD. 2004:466-491. New York. Guilford Press.
Najavits LM. Psychosocial treatments for posttraumatic stress disorder. Nathan PE, Gorman EM, editors. A guide to treatments that work. 3d ed. 2007:513-530. New York. Oxford Press.
Najavits LM. Seeking safety: An evidence-based model for substance abuse and trauma/PTSD. Therapist’s guide to evidence-based relapse prevention. 2007:141-167. San Diego, CA. Elsevier Academic Press.
Najavits LM, Griffin ML, Luborsky L, Frank A, Weiss RD, Liese BS, et al. Therapists’ emotional reactions to substance abusers: A new questionnaire and initial findings. Psychotherapy: Theory, Research, Practice, Training. 1995;32:669-677.
Najavits LM, Harned MS, Gallop RJ, Butler SF, Barber JP, Thase ME, et al. Six-month treatment outcomes of cocaine-dependent patients with and without PTSD in a multisite national trial. Journal of Studies on Alcohol and Drugs. 2007;68:353-361. [pmid: 17446974].
Najavits LM, Norman SB, Kivlahan D, Kosten TR. Improving PTSD/substance abuse treatment in the VA: A survey of providers. The American Journal on Addictions. 2010;19:257-263. [pmid: 20525033].
Najavits LM, Ryngala D, Back SE, Bolton E, Mueser KT, Brady KT. Treatment of PTSD and comorbid disorders. Foa EB, Keane TM, Friedman MJ, Cohen JA, editors. Effective treatments for PTSD: Practice guidelines from the International Society for Traumatic Stress Studies. 2nd ed. 2009:508-535. New York. Guilford Press.
Najavits LM, Sonn J, Walsh M, Weiss RD. Domestic violence in women with PTSD and substance abuse. Addictive Behaviors. 2004;29:707-715. [pmid: 15135552].
Najavits LM, Weiss RD, Reif S, Gastfriend DR, Siqueland L, Barber JP, et al. The Addiction Severity Index as a screen for trauma and posttraumatic stress disorder. Journal of Studies on Alcohol. 1998;59:56-62. [pmid: 9498316].
Najavits LM, Weiss RD, Shaw SR. The link between substance abuse and post-traumatic stress disorder in women: A research review. American Journal on Addictions. 1997;6:273-283. [pmid: 9398925].
National Association of State Mental Health Program Directors. 2005. Trauma Informed Care (TIC) planning guidelines for use in developing an organizational action plan: Transforming cultures of care toward recovery oriented services: Guidelines toward creating a trauma informed system of care. Alexandria, VA. National Association of State Mental Health Program Directors.
National Center for Post-Traumatic Stress Disorder. 2002. Working with trauma survivors: A National Center for PTSD fact sheet. Washington, DC. National Center for PTSD.
National Child Traumatic Stress Network. 2013. Types of traumatic stress. Retrieved on December 16, 2013, from: http://www.nctsn.org/trauma-types.
National Child Traumatic Stress Network, Child Sexual Abuse Task Force and Research & Practice Core. 2004. How to implement trauma-focused cognitive behavioral therapy (TF-CBT). Los Angeles. National Child Traumatic Stress Network.
National Child Traumatic Stress Network & National Center for PTSD. 2012. Psychological first aid. Retrieved on November 21, 2013, from: http://www.nctsn.org/print/795.
National Coalition for the Homeless. 2002. Why are people homeless?. Washington, DC. National Coalition for the Homeless.
National Institute of Mental Health. 2002. Mental health and mass violence: Evidence-based early psychological intervention for victims/survivors of mass violence, a workshop to reach consensus on best practices. Washington, DC. U. S. Government Printing Office.
Neuner F, Schauer M, Klaschik C, Karunakara U, Elbert T. A comparison of narrative exposure therapy, supportive counseling, and psychoeducation for treating posttraumatic stress disorder in an African refugee settlement. Journal of Consulting and Clinical Psychology. 2004;72:579-587. [pmid: 15301642].
Neuner F, Schauer M, Roth WT, Elbert T. A narrative exposure treatment as intervention in a refugee camp: A case report. Behavioural and Cognitive Psychotherapy. 2002;30:205-210.
New Logic Organizational Learning. 2011. Creating a culture of care: A toolkit for creating a trauma-informed environment. Retrieved on November 21, 2013, from: http://www.dshs.state.tx.us/cultureofcare/toolkit.doc.
New South Wales Institute of Psychiatry and Centre for Mental Health. 2000. Disaster mental health response handbook: An educational resource for mental health professionals involved in disaster management. Sydney, Australia. New South Wales Institute of Psychiatry and Center for Mental Health.
Newell JM, MacNeil GA. Professional burnout, vicarious trauma, secondary traumatic stress, and compassion fatigue: A review of theoretical terms, risk factors, and preventive methods for clinicians and researchers. Best Practices in Mental Health: An International Journal. 2010;6:57-68.
Nishith P, Mechanic MB, Resick PA. Prior interpersonal trauma: The contribution to current PTSD symptoms in female rape victims. Journal of Abnormal Psychology. 2000;109:20-25. [pmid: 10740932].
Nishith P, Resick PA, Griffin MG. Pattern of change in prolonged exposure and cognitive-processing therapy for female rape victims with posttraumatic stress disorder. Journal of Consulting and Clinical Psychology. 2002;70:880-886. [pmid: 12182271].
Nixon RDV, Nearmy DM. Treatment of comorbid posttraumatic stress disorder and major depressive disorder: A pilot study. Journal of Traumatic Stress. 2011;24:451-455. [pmid: 21755543].
Noll JG, Horowitz LA, Bonanno GA, Trickett PK, Putnam FW. Revictimization and self-harm in females who experienced childhood sexual abuse: Results from a prospective study. Journal of Interpersonal Violence. 2003;18:1452-1471. [pmid: 14678616].
North CS, Eyrich KM, Pollio DE, Spitznagel EL. Are rates of psychiatric disorders in the homeless population changing?. American Journal of Public Health. 2004;94:103-108. [pmid: 14713706].
O’Donnell C, Cook JM. 2006. Cognitive–behavioral therapies for psychological trauma and comorbid substance use disorders. Carruth B, editor. Psychological trauma and addiction treatment. New York. Haworth Press.
Office of Applied Studies. 2002. Results from the 2001 National Household Survey on Drug Abuse: Vol.1., Summary of national findings. HHS Publication No. SMA 02-3758. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Ohio Legal Rights Service. 2007. Trauma informed treatment in behavioral health settings. Columbus, OH. Ohio Legal Rights Service.
Olff M, Langeland W, Draijer N, Gersons BPR. Gender differences in posttraumatic stress disorder. Psychological Bulletin. 2007;133:183-204. [pmid: 17338596].
Ompad DC, Ikeda RM, Shah N, Fuller CM, Bailey S, Morse E, et al. Childhood sexual abuse and age at initiation of injection drug use. American Journal of Public Health. 2005;95:703-709. [pmid: 15798133].
Osterman JE, de Jong JTVM. Cultural issues and trauma. Friedman MJ, Keane TM, Resick PA, editors. Handbook of PTSD: Science and practice. 2007:425-446. Guilford Press. New York.
Ouimette P, Ahrens C, Moos RH, Finney JW. During treatment changes in substance abuse patients with posttraumatic stress disorder: The influence of specific interventions and program environments. Journal of Substance Abuse Treatment. 1998;15:555-564. [pmid: 9845869].
Ouimette P, Brown PJ. 2003. Trauma and substance abuse: Causes, consequences, and treatment of comorbid disorders. Washington, DC. American Psychological Association.
Paranjape A, Liebschutz J. STaT: A three-question screen for intimate partner violence. Journal of Women’s Health (Larchment). 2003;12:233-239.
Paulson DS, Krippner S. 2007. Haunted by combat: Understanding PTSD in war veterans including women, reservists, and those coming back from Iraq. Westport, CT. Praeger Security International.
Pearlman LA, Saakvitne KW. 1995. Trauma and the therapist: Countertransference and vicarious traumatization in psychotherapy with incest survivors. New York. WW Norton and Co.
Pennebaker JW, Kiecolt-Glaser JK, Glaser R. Disclosure of traumas and immune function: Health implications for psychotherapy. Journal of Consulting and Clinical Psychology. 1988;56:239-245. [pmid: 3372832].
Pietrzak RH, Goldstein RB, Southwick SM, Grant BF. Personality disorders associated with full and partial posttraumatic stress disorder in the U.S. population: Results from Wave 2 of the National Epidemiologic Survey on Alcohol and Related Conditions. Journal of Psychiatric Research. 2011;45:678-686. [pmid: 20950823].
Pope KS, Brown LS. 1996. Recovered memories of abuse: Assessment, therapy, forensics. Washington, D.C. American Psychological Association.
Prescott L, Soares P, Konnath K, Bassuk E. 2008. A long journey home: A guide for creating trauma-informed services for mothers and children experiencing homelessness. Retrieved on November 21, 2013, from: http://www.familyhomelessness.org/media/89.pdf.
Prins A, Ouimette P, Kimerling R, Cameron RP, Hugelshofer DS, Shaw-Hegwer J, et al. The Primary Care PTSD Screen (PC-PTSD): Development and operating characteristics. Primary Care Psychiatry. 2004;9:9-14.
Read JP, Bollinger AR, Sharkansky E. Assessment of comorbid substance use disorder and posttraumatic stress disorder. Ouimette P, Brown PJ, editors. Trauma and substance abuse: Causes, consequences, and treatment of comorbid disorders. 2003:111-125. Washington, DC. American Psychological Association.
Reivich KJ, Seligman ME, McBride S. Master resilience training in the U.S. Army. American Psychologist. 2011;66:25-34. [pmid: 21219045].
Resick PA. Cognitive therapy for posttraumatic stress disorder. Journal of Cognitive Psychotherapy: An International Quarterly. 2001;15:321-329.
Resick PA, Nishith P, Griffin MG. How well does cognitive–behavioral therapy treat symptoms of complex PTSD? An examination of child sexual abuse survivors within a clinical trial. CNS Spectrums. 2003;8:340-355. [pmid: 12766690].
Resick PA, Nishith P, Weaver TL, Astin MC, Feuer CA. A comparison of cognitive-processing therapy with prolonged exposure and a waiting condition for the treatment of chronic posttraumatic stress disorder in female rape victims. Journal of Consulting & Clinical Psychology. 2002;70:867-879. [pmid: 12182270].
Resick PA, Schnicke MK. Cognitive processing therapy for sexual assault victims. Journal of Consulting and Clinical Psychology. 1992;60:748-756. [pmid: 1401390].
Resick PA, Schnicke MK. 1993. Cognitive processing therapy for rape victims: A treatment manual. Newbury Park, CA. Sage Publications.
Resick PA, Schnicke MK. 1996. Cognitive processing therapy for rape victims: A treatment manual. Newbury Park, CA. Sage Publications, Inc.
Resnick HS, Acierno R, Kilpatrick DG, Holmes M. Description of an early intervention to prevent substance abuse and psychopathology in recent rape victims. Behavior Modification. 2005;29:156-188. [pmid: 15557482].
Reynolds M, Mezey G, Chapman M, Wheeler M, Drummond C, Baldacchino A. Co-morbid post-traumatic stress disorder in a substance misusing clinical population. Drug and Alcohol Dependence. 2005;77:251-258. [pmid: 15734225].
Riggs DS, Monson CM, Glynn SM, Canterino J. Couple and family therapy for adults. Foa EB, Keane TM, Friedman MJ, Cohen JA, editors. Effective treatments for PTSD: Practice guidelines from the International Society for Traumatic Stress Studies. 2nd ed. 2009:458-478. New York. Guilford Press.
Rothbaum BO, Meadows EA, Resick P, Foy DW. Cognitive–behavioral therapy. Foa EB, Keane TM, editors. Effective treatments for PTSD: Practice guidelines from the International Society for Traumatic Stress Studies. 2000:60-83. New York. Guilford Press.
Roy-Byrne PP, Russo J, Michelson E, Zatzick D, Pitman RK, Berliner L. Risk factors and outcome in ambulatory assault victims presenting to the acute emergency department setting: implications for secondary prevention studies in PTSD. Depression and Anxiety. 2004;19:77-84. [pmid: 15022142].
Saakvitne KW, Pearlman LA. Traumatic Stress Institute/Center for Adult & Adolescent Psychotherapy. 1996. Transforming the pain: A workbook on vicarious traumatization. 1st ed. New York. WW Norton and Co.
Salasin S. Sine qua non for public health. National Council Magazine. 2011;18.
Salyers MP, Evans LJ, Bond GR, Meyer PS. Barriers to assessment and treatment of posttraumatic stress disorder and other trauma-related problems in people with severe mental illness: Clinician perspectives. Community Mental Health Journal. 2004;40:17-31. [pmid: 15077726].
San Diego Trauma Informed Guide Team. 2012. Are you asking the right questions? A client centered approach. Retrieved on November 21, 2013, from: http://www.elcajoncollaborative.org/uploads/1/4/1/5/1415935/sd_tigt_brochure2_f.pdf.
Santa Mina EE, Gallop RM. Childhood sexual and physical abuse and adult self-harm and suicidal behaviour: A literature review. Canadian Journal of Psychiatry. 1998;43:793-800.
Saxon AJ, Davis TM, Sloan KL, McKnight KM, Jeammet P, Kivlahan DR. Trauma, symptoms of posttraumatic stress disorder, and associated problems among incarcerated veterans. Psychiatric Services. 2001;52:959-964. [pmid: 11433115].
Schein LA, Spitz HI, Burlingame GM, Muskin PR. 2006. Psychological effects of catastrophic disasters: Group approaches to treatment. New York. Haworth Press.
Schulz PM, Marovic-Johnson D, Huber LC. Cognitive-behavioral treatment of rape- and war-related posttraumatic stress disorder with a female, Bosnian refugee. Clinical Case Studies. 2006;5:191-208.
Schwartzbard R. 1997. On the scene report of the Missouri floods. Retrieved on November 21, 2013, from: http://www.aaets.org/arts/art23.htm.
Segal ZV, Williams JMG, Teasdale JD. 2002. Mindfulness-based cognitive therapy for depression: A new approach to preventing relapse. New York. Guilford Press.
Seidler GH, Wagner FE. Comparing the efficacy of EMDR and trauma-focused cognitive-behavioral therapy in the treatment of PTSD: A meta-analytic study. Psychological Medicine. 2006;36:1515-1522. [pmid: 16740177].
Shapiro F. 2001. Eye movement desensitization and reprocessing (EMDR): Basic principles, protocols, and procedures. 2nd ed. New York. Guilford Press.
Sholomskas DE, Carroll KM. One small step for manuals: Computer-assisted training in twelve-step facilitation. Journal of Studies on Alcohol. 2006;67:939-945. [pmid: 17061013].
Shoptaw S, Stein JA, Rawson RA. Burnout in substance abuse counselors: Impact of environment, attitudes, and clients with HIV. Journal of Substance Abuse Treatment. 2000;19:117-126. [pmid: 10963923].
Silver RC, Poulin M, Holman EA, McIntosh DN, Gil-Rivas V, Pizarro J. Exploring the myths of coping with a national trauma: A longitudinal study of responses to the September 11th terrorist attacks. Journal of Aggression, Maltreatment & Trauma. 2004;9:129-141.
Slattery SM, Goodman LA. Secondary traumatic stress among domestic violence advocates: Workplace risk and protective factors. Violence Against Women. 2009;15:1358-1379. [pmid: 19809098].
Smith BW, Ortiz JA, Steffen LE, Tooley EM, Wiggins KT, Yeater EA, et al. Mindfulness is associated with fewer PTSD symptoms, depressive symptoms, physical symptoms, and alcohol problems in urban firefighters. Journal of Consulting and Clinical Psychology. 2011;79:613-617. [pmid: 21875175].
Smith DW, Christiansen EH, Vincent RD, Hann NE. Population effects of the bombing of Oklahoma City. Journal of the Oklahoma State Medical Association. 1999;92:193-198. [pmid: 10213972].
Smyth JM, Hockemeyer JR, Tulloch H. Expressive writing and post-traumatic stress disorder: Effects on trauma symptoms, mood states, and cortisol reactivity. British Journal of Health Psychology. 2008;13:85-93. [pmid: 18230238].
Spitzer C, Vogel M, Barnow S, Freyberger HJ, Grabe HJ. Psychopathology and alexithymia in severe mental illness: the impact of trauma and posttraumatic stress symptoms. European Archives of Psychiatry and Neurological Sciences. 2007;257:191-196.
Sprang G, Clark JJ, Whitt-Woosley A. Compassion fatigue, compassion satisfaction, and burnout: Factors impacting a professional’s quality of life. Journal of Loss and Trauma. 2007;12:259-280.
Stamm BH. Work related secondary traumatic stress. PTSD Research Quarterly. 1997;8:1-3.
Stamm BH. 2012. Professional Quality of Life: Compassion satisfaction and fatigue version 5 (ProQOL). Retrieved on November 21, 2013, from: http://proqol.org/uploads/ProQOL_5_English.pdf.
Stamm BH, Figley CR. 1996. Compassion satisfaction and fatigue test. Pocatello, ID. Idaho State University.
Stamm BH, Friedman M. Cultural diversity in the appraisal and expression of trauma. Shalev AY, Yehuda R, McFarlane AC, editors. International handbook of human response to trauma. 2000:69-85. New York. Kluwer Academic/Plenum Publishers.
Starr AJ, Smith WR, Frawley WH, Borer DS, Morgan SJ, Reinert CM, et al. Symptoms of posttraumatic stress disorder after orthopaedic trauma. Journal of Bone and Joint Surgery. 2004;86-A:1115-1121. [pmid: 15173282].
Steel Z, Chey T, Silove D, Marnane C, Bryant RA, Van OM. Association of torture and other potentially traumatic events with mental health outcomes among populations exposed to mass conflict and displacement: A systematic review and meta-analysis. JAMA. 2009;302:537-549. [pmid: 19654388].
Stewart SH, Conrod PJ. Psychosocial models of functional associations between posttraumatic stress disorder and substance use disorder. Ouimette P, Brown PJ, editors. Trauma and substance abuse: Causes, consequences, and treatment of comorbid disorders. 2003:29-55. Washington, DC. American Psychological Association.
Stewart SH, Ouimette PC, Brown PJ. Gender and the comorbidity of PTSD with substance use disorders. Kimerling R, Ouimette PC, Wolfe J, editors. Gender and PTSD. 2002:233-270. New York. Guilford Press.
Stokols D. Translating social ecological theory into guidelines for community health promotion. American Journal of Health Promotion. 1996;10:282-298. [pmid: 10159709].
Substance Abuse and Mental Health Services Administration. 2007. The Women, Co-Occurring Disorders and Violence Study and Children’s Subset Study: Program summary. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. 2011. Addressing viral hepatitis in people with substance use disorders. Treatment Improvement Protocol (TIP) Series 53. HHS Publication No SMA 11-4656. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. 2011. Managing chronic pain in adults with or in recovery from substance use disorders. Treatment Improvement Protocol (TIP) Series 54. HHS Publication No. SMA 11-4661. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. 2012. SAMHSA’s working definition of trauma and principles and guidance for a trauma-informed approach. [Draft]. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. 2013. Addressing the specific behavioral health needs of men. Treatment Improvement Protocol (TIP) Series 56. HHS Publication No. SMA 13-4736. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. 2013. Behavioral health services for people who are homeless. Treatment Improvement Protocol (TIP) Series 55-R. HHS Publication No. SMA 13-4734. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. (planned a). Behavioral health services: Building health, wellness, and quality of life for sustained recovery. Treatment Improvement Protocol (TIP) Series. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. (planned b). Behavioral health services for American Indians and Alaska Natives. Treatment Improvement Protocol (TIP) Series. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. (planned c). Improving cultural competence. Treatment Improvement Protocol (TIP) Series. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. (planned d). Managing anxiety symptoms in behavioral health services. Treatment Improvement Protocol (TIP) Series. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. (planned e). Relapse prevention and recovery promotion in behavioral health services. Treatment Improvement Protocol (TIP) Series. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. (planned f). Reintegration-related behavioral health issues in veterans and military families. Treatment Improvement Protocol (TIP) Series. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. (planned g). Using technology-based therapeutic tools in behavioral health services. Treatment Improvement Protocol (TIP) Series. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration & Office of Applied Studies. 2008. Impact of hurricanes Katrina and Rita on substance use and mental health. (Rep No January 31). Rockville, MD. Substance Abuse and Mental Health Services Administration & Office of Applied Studies.
Suvak M, Maguen S, Litz BT, Silver RC, Holman EA. Indirect exposure to the September 11 terrorist attacks: Does symptom structure resemble PTSD?. Journal of Traumatic Stress. 2008;21:30-39. [pmid: 18302169].
Tanielian T, Jaycox LH. 2008. Invisible wounds of war: Psychological and cognitive injuries, their consequences, and services to assist recovery. Washington, DC. RAND Centre for Military Health Policy Research.
Teicher MH. Scars that won’t heal: The neurobiology of child abuse. Scientific American. 2002;286:68-75. [pmid: 11857902].
Tolin DF, Foa EB. Sex differences in trauma and posttraumatic stress disorder: A quantitative review of 25 years of research. Psychological Bulletin. 2006;132:959-992. [pmid: 17073529].
Toussaint DW, VanDeMark NR, Bornemann A, Graeber CJ. Modifications to the trauma recovery and empowerment model (TREM) for substance-abusing women with histories of violence: Outcomes and lessons learned at a Colorado substance abuse treatment center. Journal of Community Psychology. 2007;35:879-894.
Tri-County Mental Health Services. 2008. You and Tri-county: Consumer rights and concerns. Retrieved on November 21, 2013, from: http://tcmhs.org/pdfs/31288-Rightsbooklet.pdf.
Triffleman E. Gender differences in a controlled pilot study of psychosocial treatment in substance dependent patients with post-traumatic stress disorder: Design considerations and outcomes. Alcoholism Treatment Quarterly. 2000;18:113-126.
Trippany RL, Kress VEW, Wilcoxon SA. Preventing vicarious trauma: What counselors should know when working with trauma survivors. Journal of Counseling & Development. 2004;82:31-37.
Turnbull GJ. A review of post-traumatic stress disorder; part I: Historical development and classification. Injury. 1998;29:87-91. [pmid: 10721399].
U.S. Committee for Refugees and Immigrants. 2006. World Refugee Survey 2006: Risks and rights. Arlington, VA. U.S. Committee for Refugees and Immigrants.
U.S. Department of Health and Human Services, Health Resources and Services Administration. 2006. Model trauma system: Planning and evaluation. Rockville, MD. US Department of Health and Human Services, Health Resources and Services Administration.
U.S. Department of Health and Human Services. 2003. Developing cultural competence in disaster mental health programs: Guiding principles and recommendations. (Rep No. HHS Pub No SMA 03-3828). Rockville, MD. Center for Mental Health Services, Substance Abuse and Mental Health Services Administration.
U.S. Department of Housing and Urban Development & Office of Community Planning and Development. 2007. The annual homeless assessment report to Congress. Retrieved November 21, 2013, from: http://www.huduser.org/Publications/pdf/ahar.pdf.
U.S. Department of Veterans Affairs & U.S. Department of Defense. 2010. VA/DoD clinical practice guideline for management of post-traumatic stress. Washington, DC. Department of Veterans Affairs, Department of Defense.
U.S. Fire Administration. 2007. I-35W bridge collapse and response: Technical report series USFA-TR-166 August. Emmittsburg, MD. U.S. Fire Administration.
University of South Florida College of Behavioral, Community Sciences. 2012. Creating trauma-informed care environments: An organizational self-assessment. Retrieved on November 21, 2013, from: http://www.cfbhn.org/assets/TIC/youthresidentialselfassessFillableFORM%20%282%29.pdf.
Vaishnavi S, Connor K, Davidson JRT. An abbreviated version of the Connor-Davidson Resilience Scale (CD-RISC), the CD-RISC2: Psychometric properties and applications in psychopharmacological trials. Psychiatry Research. 2007;152:293-297. [pmid: 17459488].
Valent P. Diagnosis and treatment of helper stresses, traumas, and illnesses. Figley CR, editor. Treating compassion fatigue. 2002:17-38. New York. Brunner-Routledge.
Valentine PV, Smith TE. Evaluating traumatic incident reduction therapy with female inmates: A randomized controlled clinical trial. Research on Social Work Practice. 2001;11:40-52.
van der Kolk BA, McFarlane AC, Van der Hart O. A general approach to treatment of posttraumatic stress disorder. van der Kolk BA, McFarlane AC, Weisaeth L, editors. Traumatic stress: The effects of overwhelming experience on mind, body, and society. 1996:417-440. New York. Guilford Press.
van der Kolk BA, McFarlane AC, Weisaeth L. 1996. Traumatic stress: the effects of overwhelming experience on mind, body, and society. New York. Guilford Press.
van der Kolk B, Roth S, Pelcovitz D, Mandel F. 1993. Complex PTSD: Results of the PTSD field trials for DSM-IV. Washington, DC. American Psychiatric Association.
Van Emmerik AAP, Kamphuis JH, Hulsbosch AM, Emmelkamp PMG. Single session debriefing after psychological trauma: A meta-analysis. Lancet. 2002;360:766-771. [pmid: 12241834].
Varra AA, Follette VM. ACT with posttraumatic stress disorder. Hayes SC, editor. A practical guide to acceptance and commitment therapy. 2005:133-152. New York. Springer Science & Business Media.
Vlahov D, Galea S, Ahern J, Resnick H, Kilpatrick D. Sustained increased consumption of cigarettes, alcohol, and marijuana among Manhattan residents after September 11, 2001. American Journal of Public Health. 2004;94:253-254. [pmid: 14759935].
Vo NM. 2006. The Vietnamese boat people, 1954 and 1975–1992. Jefferson, NC. McFarland & Co.
Vogt D, Bruce TA, Street AE, Stafford J. Attitudes toward women and tolerance for sexual harassment among reservists. Violence Against Women. 2007;13:879-900. [pmid: 17704049].
Von Rueden KT, Hinderer KA, McQuillan KA, Murray M, Logan T, Kramer B, et al. Secondary traumatic stress in trauma nurses: Prevalence and exposure, coping, and personal/environmental characteristics. Journal of Trauma Nursing. 2010;17:191-200. [pmid: 21157252].
Wagnild GM, Young HM. Development and psychometric evaluation of the Resilience Scale. Journal of Nursing Measurement. 1993;1:165-178. [pmid: 7850498].
Waldrop AE, Back SE, Verduin ML, Brady KT. Triggers for cocaine and alcohol use in the presence and absence of posttraumatic stress disorder. Addictive Behaviors. 2007;32:634-639. [pmid: 16863682].
Walser RD. Disaster response: Professional and personal journeys at the Pentagon. The Behavior Therapist. 2004;25:27-30.
Way I, VanDeusen KM, Martin G, Applegate B, Jandle D. Vicarious trauma: A comparison of clinicians who treat survivors of sexual abuse and sexual offenders. Journal of Interpersonal Violence. 2004;19:49-71. [pmid: 14680529].
Weathers FW, Litz BT, Herman DS, Huska JA, Keane TM. 1993. The PTSD checklist: Reliability, validity, and diagnostic utility. Paper presented at the Annual Meeting of the International Society for Traumatic Stress Studies. San Antonio, TX.
Weine S, Danieli Y, Silove D, Ommeren MV, Fairbank JA, Saul J. Guidelines for international training in mental health and psychosocial interventions for trauma exposed populations in clinical and community settings. Psychiatry. 2002;65:156-164. [pmid: 12108139].
Weiss D, Marmar C. The Impact of Event Scale-revised. Wilson J, Keane T, editors. Assessing psychological trauma and PTSD. 1997:399-411. New York. Guildford Press.
Weiss L, Fabri A, McCoy K, Coffin P, Netherland J, Finkelstein R. A vulnerable population in a time of crisis: Drug users and the attacks on the World Trade Center. Journal of Urban Health: Bulletin of the New York Academy of Medicine. 2002;79:392-403. [pmid: 12200508].
Wessely S, Bryant RA, Greenberg N, Earnshaw M, Sharpley J, Hughes JH. Does psychoeducation help prevent posttraumatic psychological distress?. Psychiatry: Interpersonal and Biological Processes. 2008;71:287-302.
Westermeyer J. Cross-cultural aspects of substance abuse. Galanter M, Kleber HD, editors. The American Psychiatric Publishing textbook of substance abuse treatment. 3rd ed. 2004:89-98. Washington, DC. American Psychiatric Publishing.
Whitbeck LB, Chen X, Hoyt DR, Adams GW. Discrimination, historical loss and enculturation: culturally specific risk and resiliency factors for alcohol abuse among American Indians. Journal of Studies on Alcohol. 2004;65:409-418. [pmid: 15376814].
White M. 2004. Narrative therapy. Retrieved on November 21, 2013, from: http://www.massey.ac.nz/~alock/virtual/white.htm.
Wilson JP, Tang CS. 2007. Cross-cultural assessment of psychological trauma and PTSD. New York. Springer Publishing.
Wolfe J, Kimerling R. Gender issues in the assessment of posttraumatic stress disorder. Wilson JP, Keane TM, editors. Assessing psychological trauma and PTSD. 1997:192-238. New York. Guilford Press.
Wolpe J. 1958. Psychotherapy by reciprocal inhibition. Stanford, CA. Stanford University Press.
Wolpe J, Abrams J. Post-traumatic stress disorder overcome by eye-movement desensitization: A case report. Journal of Behavior Therapy and Experimental Psychiatry. 1991;22:39-43. [pmid: 1680883].
Wong PTP, Wong LCJ. 2006. Handbook of multicultural perspectives on stress and coping. Dallas, TX. Spring Publications.
World Health Organization. 1992. International statistical classification of diseases and related health problems. 10th revision ed. Geneva, Switzerland. World Health Organization.
Young MA. 2001. The community crisis response team training manual. Washington, DC. U S Department of Justice, Office of Justice Programs.
Zatzick DF, Jurkovich GJ, Gentilello L, Wisner D, Rivara FP. Posttraumatic stress, problem drinking, and functional outcomes after injury. Archives of Surgery. 2002;137:200-205. [pmid: 11822960].
Zatzick D, Roy-Byrne P, Russo J, Rivara F, Droesch R, Wagner A, et al. A randomized effectiveness trial of stepped collaborative care for acutely injured trauma survivors. Archives of General Psychiatry. 2004;61:498-506. [pmid: 15123495].
Zinzow HM, Resnick HS, Amstadter AB, McCauley JL, Ruggiero KJ, Kilpatrick DG. Drug- or alcohol-facilitated, incapacitated, and forcible rape in relationship to mental health among a national sample of women. Journal of Interpersonal Violence. 2010;25:2217-2236. [pmid: 20100896].