# Consensus Panel

## Chair

- Patrick Reilly, Ph.D.
  Associate Chief
  Mental Health Service
  Community-Based Outpatient Clinic
  Santa Rosa Veterans Affairs
  Associate Clinical Professor
  Department of Psychiatry
  University of California San Francisco
  Santa Rosa, CA

## Co-Chair

- William S. Pollack, Ph.D.
  Assistant Clinical Professor
  Department of Psychiatry
  Director
  Harvard Medical School
  Centers for Men and Young Men
  McLean Hospital
  Belmont, MA

## Workgroup Managers

- Gary R. Brooks, Ph.D.
  Professor
  Department of Psychology and Neuroscience
  Baylor University
  Temple, TX
- Thomas E. Freese, Ph.D.
  Director
  University of California–Los Angeles
  Integrated Substance Abuse Programs
  Pacific Southwest Addiction Technology Transfer Center
  Los Angeles, CA
- Glenn E. Good, Ph.D.
  Associate Professor
  Department of Educational, School and Counseling Psychology
  University of Missouri–Columbia
  Columbia, MO

## Panelists

- Louis E. Baxter, Sr., M.D., FASAM
  Executive Director
  Physicians Health Program
  Medical Society of New Jersey
  Lawrenceville, NJ
- Rodger L. Beatty, Ph.D., LSW
  Assistant Professor
  University of Pittsburgh
  Pittsburgh, PA
- Terry Beartusk, B A., CAS III
  Executive Director
  Thunder Child Treatment Center
  Sheridan, WY
- Harold O. Braithwaite, Jr., Ph.D.
  Associate Professor and Chair
  Department of Psychology
  Morehouse College
  Atlanta, GA
- John P. de Miranda, Ed.M.
  Executive Director
  National Association on Alcohol, Drugs and Disability, Inc.
  San Mateo, CA
- Robert K. Edmundson, M.A., M.S.W.
  Assistant Professor
  Department of Behavioral Medicine and Psychiatry
  West Virginia University
  Morgantown, WV
- Natarajan Elangovan, M.D., M.P.H.
  Clinical Director
  Meadowview Psychiatric Hospital
  Secaucus, NJ
- Thomas L. Geraty, Ph.D., LICSW
  Jamaica Plain, MA
- Jan Ligon, Ph.D., LCSW
  Associate Professor
  School of Social Work
  Georgia State University
  Atlanta, GA
- William M. Liu, Ph.D.
  Assistant Professor in Counseling Psychology
  Division of Psychological and Quantitative Foundations
  University of Iowa
  Iowa City, IA
- Irmo Marini, Ph.D., CRC, CLCP, FVE
  Professor, Graduate Program Coordinator
  Rehabilitative Services Program
  College of Health Sciences and Human Services
  University of Texas–Pan American
  Edinburg, TX
- Thomas J. McMahon, Ph.D.
  Assistant Professor
  Yale University School of Medicine
  West Haven, CT
- Michael Mobley, Ph.D., M.Ed.
  Assistant Professor in Counseling Psychology
  Department of Educational, School and Counseling Psychology
  University of Missouri–Columbia
  Columbia, MO
- Jerry Pattillo, Ph.D.
  Chief, Chemical Dependency Services
  Department of Psychiatry
  Kaiser Medical Center
  San Francisco, CA
- Thomas A. Peltz, M.Ed., CAS
  Therapist/Licensed Mental Health Counselor
  Private Practice
  Beverly Farms, MA
- David J. Powell, Ph.D.
  President
  International Center for Health Concerns, Inc.
  East Granby, CT
- Luis B. Rosell, M.A., Psy.D.
  Licensed Clinical Psychologist
  LBR Psychological Consultants
  Mount Pleasant, IA
- Eddie B. Sample, Jr., M.S.Ed.
  Research Associate
  Rehabilitation, Research and Training Center on Drugs and Disability
  Wright State University
  Trotwood, OH
- Bernard Segal, Ph.D.
  Director
  Center for Alcohol and Addiction Studies
  University of Alaska–Anchorage
  Anchorage, AK

## Addiction Technology Transfer Center Representative

- John Porter
  Technology Transfer Specialist
  Northwest Frontier Addiction Technology Transfer Center
  Salem, OR