# Executive Summary

This Treatment Improvement Protocol (TIP) is a companion to TIP 51, Substance Abuse Treatment: Addressing the Specific Needs of Women. These two volumes look at how gender-specific treatment strategies can improve outcomes for men and women, respectively. The physical, psychological, social, and spiritual effects of substance use and abuse on men can be quite different from the effects on women, and those differences have implications for treatment in behavioral health settings. Men are also affected by social and cultural forces in different ways than women, and physical differences between the genders influence substance use and recovery as well. This TIP, Addressing the Specific Behavioral Health Needs of Men, addresses these distinctions. It provides practical information based on available evidence and clinical experience that can help counselors more effectively treat men with substance use disorders.

Historically, standard behavioral health services for substance abuse have been designed with male clients in mind. As the number of women presenting for substance abuse services increased, clinicians began to understand that women had different treatment needs than men, related to differences in their patterns of substance use and their perceptions of both the problem of substance abuse and its treatment. Researchers began to investigate how standard substance abuse treatment in a variety of behavioral health settings can be altered to improve outcomes for women. In the process, they have gained insight into how men's and women's responses to substance abuse and substance abuse treatment differ. These insights can also improve treatment for men. New research in the areas of gender studies and men's studies can help providers understand why men abuse substances and how to address masculine values in treatment.

## Why Are Men at Greater Risk for Substance Abuse?

Men in America today may have advantages that women lack. However, in spite of these advantages, men die at a younger age on average than women; men are also more likely than women to have a substance use disorder, to be incarcerated, to be homeless as adults, to die of suicide, and to be victims of violent crime. Conversely, men are less likely than women to seek medical help or behavioral health counseling for any of the problems they face. These significant problems, combined with men's tendency to avoid addressing them, call for a response from behavioral health treatment providers. It is the consensus panel's hope that this TIP will begin to focus providers' and researchers' attention on the diverse problems that men with substance use disorders face and to serve as both an introduction to the topic and a summary of what is known regarding the subject to date.

## How Is the Term “Substance Abuse” Used?

In this TIP, the term “substance abuse” refers to either substance abuse or substance dependence or both (as defined by the Diagnostic and Statistical Manual of Mental Disorders, 4th Edition, Text Revision [DSM-IV-TR]; American Psychiatric Association 2000) and encompasses the use of both alcohol and other psychoactive substances. Though unfortunately ambiguous, this term was chosen partly because the lay public, policymakers, and many substance abuse treatment professionals commonly use “substance abuse” to describe any excessive or pathological use of any addictive substance. Readers should attend to the context in which the term occurs to determine the range of possible meanings; in most cases, however, the term refers to all substance use disorders described by the DSM-IV-TR.

## Who Can Use This TIP?

This TIP is addressed to the variety of behavioral health service providers in a variety of treatment settings who may be involved with helping men recognize their need for treatment, mobilize to access appropriate care, participate in substance abuse treatment interventions, involve their families and significant others in recovery, and continue services in extended recovery. Although traditional substance abuse treatment has been provided in settings that are specific to substance use disorders, this TIP recognizes that treatment for substance abuse today can occur in a variety of behavioral health settings and that there is no wrong door for men to enter and participate in treatment and recovery.

## What Is This TIP's Scope?

This TIP covers many topics relating to adult men (defined here as individuals ages 18 and over) and their use of, abuse of, and/or dependence on substances. What this TIP does not cover are the substance use patterns and treatment of boys and adolescents, as they form a distinct population with particular treatment needs. TIPs 31, Screening and Assessing Adolescents for Substance Use Disorders (Center for Substance Abuse Treatment [CSAT] 1999c), and 32, Treatment of Adolescents With Substance Use Disorders (CSAT 1999d), address substance abuse assessment and treatment, respectively, for both male and female adolescents. Please note, however, that some of the research used in this TIP does include men younger than 18, and in these cases the text indicates the age group referenced.

The TIP represents the view of the consensus panel that a clear link exists between the social and cultural environment within which many boys are raised and the difficulty that many men have in seeking help from others. Pressures on men and boys can stem from expectations to conform to society's view of the ideal man—successful, accomplished, independent, and self-sufficient—which sometimes conflicts with a man's need to seek help. Additionally, when men do need help, such as in substance abuse treatment or other behavioral health services, negative consequences may arise, such as stress, anxiety, shame, rejection, low self-esteem, depression, and other mental problems that have been sedated or disguised by the substance use. These secondary effects can complicate the efforts of many men to seek help for their behavioral health needs.

In recent years, there has been increased awareness of the extent of women's substance abuse, but men in the United States are two to five times more likely to develop a substance use disorder than women (depending on the study). Research shows men are less likely to seek help for medical or behavioral health problems; even so, the majority of clients entering substance abuse treatment are male.

### Chapter 1: Creating the Context

Much of this TIP is premised on the understanding that stereotypes of masculine behavior shape men's attitudes, beliefs, and behaviors (including those related to substance use and abuse). These socially defined concepts of masculinity push men in our culture to restrict their emotional responsiveness, be more competitive, be more aggressive, and be self-reliant. Masculine roles may also hinder some men from seeking needed treatment for a variety of health, and particularly behavioral health, concerns, including those related to mental illness and substance abuse.

Concepts of masculinity affect different men to different degrees, but no man is unaffected by them or by the ways in which proper masculine behavior is defined at a societal level. Not all effects of masculine ideologies are negative, however, and traditional masculine values can be helpful or beneficial. Also, although there are certain masculine values that are dominant in contemporary American culture and fairly common across cultures, some cultures may define masculinity differently. Masculine values may also differ according to the role a man is filling (e.g., father, brother, friend).

In addition to explaining some of the research on masculinity, the first chapter defines other key concepts, such as gender, sex, and substance use disorders. It also presents some basic information on men's substance use and abuse in relation to that of women. Finally, it discusses the current state of the behavioral health field in regards to male-specific substance abuse treatment, what the future may hold for male-informed treatment, and how various audiences can use this TIP.

### Chapter 2: Screening and Assessment

The screening and assessment of substance use disorders is an important and ongoing facet of treatment that should be adapted to the needs of the individual client. Part of this process of tailoring screening and assessment to client needs is being aware of how a man's beliefs and concerns about his identity as a man affect how he responds to screening and assessment questions and procedures—by doing so, clinicians will be better able to engage men in this process.

This chapter reviews three parts of a comprehensive screening and assessment process, which are:

1. The screening.
2. An assessment of the presenting problem (e.g., substance abuse) and its social, spiritual, psychological, and medical consequences.
3. A personal assessment that investigates other behaviors, values, attitudes, and experiences that may influence treatment in behavioral health settings.

Throughout this process, clinicians should be aware of the ways in which male gender roles influence men's psychosocial adaptation, substance use/abuse, and help-seeking behaviors.

Men are often ambivalent about seeking help for health problems (whether related to behavioral or physical health), and clinicians should acknowledge and possibly discuss this ambivalence with the client before assessment commences. Furthermore, many men are typically embarrassed or reluctant to talk about feelings. Providers can acknowledge this difficulty and work with clients to make the process less threatening. Because men are often action-oriented and focused on the concrete, it is helpful to present specific goals in the assessment process and sometimes to use visual representations of their problems and past experiences.

Although screening for and assessment of substance use disorders are among the primary goals of behavioral health service providers, there are a number of other factors that can affect treatment that need to be investigated as part of a comprehensive personal assessment. Some of these areas will be investigated in almost every case, others will be pursued if particular information surfaces during the screening, and still other areas will only be investigated if the client expresses interest or concern. The chapter briefly considers the following areas of assessment:

- Work/employment history
- Housing status and needs
- Criminal justice involvement and legal issues
- Physical health
- Functional limitations
- Co-occurring mental disorders
- Trauma histories
- Motivation to change
- Relapse risk and recovery support
- Spiritual and religious beliefs

In addition, the chapter provides a more indepth consideration of the assessment of family history (including both childhood abuse and current domestic violence), male sexuality, and shame.

### Chapter 3: Treatment Issues

Chapter 3 explores issues that may affect substance abuse treatment for most, if not all, men. It begins with a discussion of some general considerations about how masculine roles may affect men in treatment, men's treatment-seeking behavior, and methods of engaging men in substance abuse treatment.

The chapter then discusses at length the issue of gender dynamics, transference, and counter-transference for male and female behavioral health counselors working with male clients. Case examples are given to highlight some potential problems that can arise. The chapter also discusses the pros and cons of having either male or female counselors working with male clients. Because the majority of substance abuse treatment clients are male but most counselors are female, the chapter also includes some ideas about recruiting male counselors.

A variety of social and behavioral issues can affect men's patterns of substance use/abuse as well as their success in treatment. These issues include counseling men who have difficulties expressing emotion and men who feel excessive shame, both common problems for men in substance abuse treatment. Male roles and training may result in difficulties accessing some or all emotions, or in problems reacting appropriately to some emotions, such as anger. Men are affected by different kinds of shame and social stigma than women, and men are expected to engage in different rituals or rites of passage, many of which involve alcohol.

Men's behaviors relating to sexuality and violence are often important issues in treatment. Men are much more likely to commit violent acts than women, and those acts of violence are often associated with substance use/abuse. Violence, criminal behavior, and anger are factors that often need to be addressed if a man is to remain substance free. Although providers may be aware of the possibility that men may commit violent acts, they are less likely to consider that men are often victims of violence as well. Clinicians often do not look for—and men are rarely forthcoming about—histories of childhood physical or sexual abuse or current victimization by domestic partners, and yet these are factors that can have a strong negative effect on treatment.

Men's sexual behavior is also often affected by their substance use/abuse, and this chapter helps behavioral health service providers understand the relationship between sexuality and substance use. It also discusses sexual dysfunction, the effects of substance abuse on the male reproductive system, sexual identity, compulsive sexual behaviors, and other issues.

Behavioral health service providers have become more aware in recent years of the importance of parenting and child custody for women entering treatment, and they have responded with the creation of programs that work with mothers and their children together. Children and other family members can also play an important role in encouraging men to enter treatment, and fears about losing custody of children can inhibit treatment entry. Men's substance abuse can have lasting effects on their children as well as themselves, and behavioral health services provide an opportunity to improve their parenting skills that many men will gladly take. This chapter provides some guidance to clinicians who want to address parenting in treatment programs for men. Reproductive responsibility, child support, and family court involvement are also discussed.

A holistic approach to treatment involves addressing men's spiritual and/or religious beliefs. Despite conflicting views among researchers and other professionals in the field about the link between spirituality and health, the consensus panel believes that spiritual beliefs and/or practices do influence some men's desire to abstain from using substances. Alcoholics Anonymous and Narcotics Anonymous are 12-Step organizations that use participants' reliance on a higher power to aid in the recovery process. These and similar groups have helped many individuals, both men and women, make tremendous progress on their road to recovery. This chapter discusses the spiritual element of 12-Step groups and the relationship between spirituality and health.

### Chapter 4: Working With Specific Populations of Men in Behavioral Health Settings

Numerous social and cultural factors either contribute to or help moderate men's substance use, including their degree of conformity to masculine roles; culture, race, ethnicity, and related issues, such as racism and acculturation; family roles (e.g., son, partner, husband, father) and history; sexual orientation; geographic location; education; and professional background. Other factors related to some men's specific circumstances (e.g., behavioral and physical health problems, unemployment or type of employment, criminal justice system involvement, homelessness) may play a significant role in men's treatment and recovery plans.

Chapter 4 explores some basic differences in men's patterns of substance use/abuse based on various demographic factors. Men typically begin using substances at a younger age than women do, and this appears to be a major factor in greater rates of substance use disorders among adult men than among women. Boys and young men may also turn to substance use/abuse for different reasons than girls and young women do. For example, early use of substances by men may be attributable to the fact that they are not adept at addressing emotional pain constructively. A man's family background, sexual orientation, and cultural/ethnic identities may also affect his choice of substances and the possibility that he will develop a substance use disorder.

Men are less likely to have a serious mental illness than women are, but men make up the majority of adults with co-occurring substance use and other mental disorders in behavioral health settings. This chapter considers rates of different co-occurring mental disorders among men and discusses how the course and presentation of different disorders may differ between the sexes. The chapter also looks at the related problem of suicidality, as men are more likely than women to die of suicide despite being less likely to attempt suicide. Physical illness or disability may also affect men's substance use/abuse; treatment may need to address those issues.

Masculine roles vary by age, as does men's substance abuse. This chapter covers special treatment needs of young men (ages 18 to 24) and older adult men (ages 65 and older). Research suggests that patterns of substance use/abuse for gay and bisexual men may differ from those of heterosexual men; a discussion of the treatment needs of gay and bisexual men is also included.

Employment has been shown to be especially important for men's success in recovery, and substance abuse is considerably higher among men who are unemployed. Rates of unemployment are very high for men entering substance abuse treatment. In some cases, occupation may also affect substance abuse for men who are employed. The chapter also discusses the role economic and cultural factors play in men's substance use/abuse.

The specific needs of male veterans are also addressed. Advice to behavioral health counselors for helping veterans access U.S. Department of Veterans Affairs (VA) services is provided, and the impact of combat stress reactions is discussed.

The special dynamics of men entering treatment through the criminal justice system or men who may interact with the criminal justice system while in substance abuse treatment are also addressed in this chapter. The criminal justice system is the largest single source of referrals to substance abuse treatment for men, and many other men receive treatment while incarcerated in jails or prisons. It is essential that behavioral health counselors understand the criminal justice system and how to interact with it appropriately.

Men typically enter substance abuse treatment with multiple needs that result, at least in part, from years of substance abuse. To address these needs, providers will often have to interact with other systems, such as the criminal justice system and the housing/homelessness services system. Homelessness has been associated with substance use disorders and co-occurring disorders among men. Men make up about four-fifths of homeless individuals in substance abuse treatment, but many programs cannot meet their particular needs—this chapter discusses ways programs can improve treatment outcomes for this group of men.

The chapter ends with coverage of broad cultural groups in the United States and the ways in which men's culture can affect their substance use/abuse and concepts of appropriate masculine roles.

### Chapter 5: Treatment Modalities and Settings

Chapter 5 describes some treatment methods that researchers and providers have found useful in helping men recover from substance use disorders. It covers men's treatment needs in the context of different modalities (e.g., group therapy, individual therapy, family therapy) and settings (e.g., outpatient, inpatient) and some of the specific types of services that may be used by programs treating men (e.g., enhancing motivation, money management).

Men tend to be more reticent in group settings than women and less willing to attend such sessions, which can account for somewhat better treatment outcomes for female clients. Providers should try to increase men's participation in groups. There are both benefits and potential problems involved in male-specific groups, and the chapter discusses some of these considerations.

Family and significant others often play an important role in motivating men to enter treatment. Once in recovery, men appear to stay with their partners more often than women who enter recovery. Couples and family therapy can therefore be important options for men in treatment. Men who are best suited for couples therapy:

- Have a high school or better education.
- Are employed or willing to be employed.
- Live with their partners or have partners willing to reconcile if they enter therapy.
- Are older.
- Have long-term substance abuse problems.
- Have recently had a crisis that may have threatened the relationship.
- Have a partner and/or other member of the household who does not abuse substances.
- Do not have other serious mental or emotional illnesses.
- Are not violent.

Some of the goals that providers should have when conducting family or couples therapy with men who are in substance abuse treatment include (1) developing perceptual and conceptual skills, (2) promoting mutual responsibility, and (3) challenging stereotypical behaviors and attitudes. Readers are cautioned that couples and family therapy is contraindicated for clients where there is a history or risk of domestic violence.

Chapter 5 covers family interventions that help men enter treatment. These range from simple methods (e.g., fielding calls to an agency from concerned significant others) to formalized intervention models (e.g., the Albany-Rochester Sequence for Engagement and Community Reinforcement and Family Training).

Chapter 5 presents information on some common treatment strategies (e.g., motivational enhancement, relapse prevention) and how they may be adapted for use with a specifically male clientele. Men often relapse for different reasons than women; relapse prevention techniques may need to take those differences into account. Men's participation in mutual-help groups is also considered.