# KAP Expert Panel and Federal Government Participants

- Barry S. Brown, Ph.D.
  Adjunct Professor
  University of North Carolina–Wilmington
  Carolina Beach, NC
- Jacqueline Butler, M.S.W., LISW, LPCC, CCDC III, CJS
  Professor of Clinical Psychiatry
  College of Medicine
  University of Cincinnati
  Cincinnati, OH
- Deion Cash
  Executive Director
  Community Treatment and Correction Center, Inc.
  Canton, OH
- Debra A. Claymore, M.Ed.Adm.
  Owner/Chief Executive Officer
  WC Consulting, LLC
  Loveland, CO
- Carlo C. DiClemente, Ph.D.
  Chair
  Department of Psychology
  University of Maryland Baltimore County
  Baltimore, MD
- Catherine E. Dube, Ed.D.
  Independent Consultant
  Brown University
  Providence, RI
- Jerry P. Flanzer, D.S.W., LCSW, CAC
  Chief, Services
  Division of Clinical and Services Research
  National Institute on Drug Abuse
  Bethesda, MD
- Michael Galer, D.B.A.
  Chairman
  Graduate School of Business
  University of Phoenix– Greater Boston Campus
  Braintree, MA
- Renata J. Henry, M.Ed.
  Director
  Division of Alcoholism, Drug Abuse, and Mental Health
  Delaware Department of Health and Social Services
  New Castle, DE
- Joel Hochberg, M.A.
  President
  Asher & Partners
  Los Angeles, CA
- Jack Hollis, Ph.D.
  Associate Director
  Center for Health Research
  Kaiser Permanente
  Portland, OR
- Mary Beth Johnson, M.S.W.
  Director
  Addiction Technology Transfer Center
  University of Missouri–Kansas City
  Kansas City, MO
- Eduardo Lopez, B.S.
  Executive Producer
  EVS Communications
  Washington, DC
- Holly A. Massett, Ph.D.
  Academy for Educational Development
  Washington, DC
- Diane Miller
  Chief
  Scientific Communications Branch
  National Institute on Alcohol Abuse and Alcoholism
  Bethesda, MD
- Harry B. Montoya, M.A.
  President/Chief Executive Officer
  Hands Across Cultures
  Espanola, NM
- Richard K. Ries, M.D.
  Director/Professor
  Outpatient Mental Health Services
  Dual Disorder Programs
  Seattle, WA
- Gloria M. Rodriguez, D.S.W.
  Research Scientist
  Division of Addiction Services
  New Jersey Department of Health and Senior Services
  Trenton, NJ
- Everett Rogers, Ph.D.
  Center for Communications Programs
  Johns Hopkins University
  Baltimore, MD
- Jean R. Slutsky, P.A., M.S.P.H.
  Senior Health Policy Analyst
  Agency for Healthcare Research and Quality
  Rockville, MD
- Nedra Klein Weinreich, M.S.
  President
  Weinreich Communications
  Canoga Park, CA
- Clarissa Wittenberg
  Director
  Office of Communications and Public Liaison
  National Institute of Mental Health
  Kensington, MD

## Consulting Members

- Paul Purnell M.A.
  Social Solutions, LLC
  Potomac, MD
- Scott Ratzan, M.D., M.P.A., M.A.
  Academy for Educational Development
  Washington, DC
- Thomas W. Valente, Ph.D.
  Director
  Master of Public Health Program
  Department of Preventive Medicine
  School of Medicine
  University of Southern California
  Alhambra, CA
- Patricia A. Wright, Ed.D.
  Independent Consultant
  Baltimore, MD