# 3 Treatment Issues for Men

## Introduction

This chapter describes specific issues facing men that can affect all elements of the treatment process, including the decision to seek treatment in the first place. Behavioral health counselors can anticipate barriers and better engage men in treatment by being aware of factors that influence why men abuse substances, which substances they choose, and the behavioral, social, and situational issues they may confront. The chapter begins by addressing co-occurring disorders—a major issue in the treatment of men—and goes on to examine social, behavioral, family, spiritual, and situational issues.

## Treating Men for Substance Abuse: General Considerations

Many treatment approaches useful for men are the same that have been found useful for all clients. As noted in Chapter 1, most clients in substance abuse treatment are male, and most research into treatment methods has used populations that reflect the composition of treatment programs. Small adaptations can be made to improve treatment for men, such as ensuring that waiting rooms have decorations and reading material that appeal to men, and asking about client preferences regarding types of treatment (many men prefer more instrumental approaches, such as cognitive–behavioral therapy) and behavioral health service provider gender (see the discussion on therapist gender later in this chapter). Providers should also recognize the motivations that typically bring men to treatment (such as criminal justice system involvement, referrals from other behavioral health resources, and family or work-related pressures, discussed in Chapter 5) and the possible resentment of treatment staff that can result. In treatment planning, consider approaches that have been found effective with men or with men who have particular characteristics (such as a high degree of anger)—these, too, are discussed in Chapter 5.

The other considerations of which behavioral health service providers need to be mindful follow from an understanding of the factors that define masculinity and male roles in our society, which are discussed in Chapter 1. Men are expected to be independent, self-sufficient, stoic, and invulnerable. Consequently, they may have trouble identifying or expressing weaknesses or problems within treatment, which may be perceived as a lack of trust or an unwillingness to be open with counselors or fellow clients. Men often have concerns about privacy and need reassurance that treatment will pose no threat to their image or standing. They may also have trouble analyzing their own problems, particularly feelings related to those problems. This too is, in part, a reflection of men's stoicism. Their need to be self-sufficient may result in a false sense of accomplishment or security in their recovery, which may manifest as unwillingness to follow through with continuing care or attend mutual-help meetings.

Men are also expected to be competitive and, at times, aggressive. As a result, male clients may develop combative or competitive relationships with male treatment group members and staff or may appear resistant to others' suggestions. They may resent being told what to do, and so suggestions may need to be reframed as conclusions that are reached collaboratively between client and counselor. Their need to prove themselves may extend into a number of different areas, including sexual accomplishment, physical domination (which can lead to violence), or competitive interactions with other clients (e.g., through the telling of war stories about their substance abuse).

### Treatment-Seeking Behaviors in Men

When screening and assessing male clients for substance use disorders, behavioral health clinicians can take a number of steps to alleviate the discomfort men may experience when seeking professional assistance. Of course, establishing rapport and trust with the client from the start is essential. Although time restrictions are a reality, clinicians can make the most of the time they do have, even if only a few minutes. From their first contact with a male client, clinicians can be sensitive to the ways traditional male gender norms may be influencing the screening and assessment process. Certain male clients feel threatened by or uncomfortable with the help-seeking process, so clinicians in behavioral health settings can spend time initially developing rapport and establishing a connection before beginning screening and assessment. In some areas, this can be done by developing kinship: for instance, knowing a bit about where the client grew up, having a common understanding of the client's work, or sharing an interest in a recreational pursuit. When establishing kinship, though, counselors should take care not to transcend confidentiality boundaries or appear too intrusive in questioning.

Although male clients may have some common attitudes and behaviors based on gender role socialization, their personal definitions of masculinity and attitudes toward behavioral health services and interventions (e.g., therapy and assessment) will vary. As much as possible, clinicians need to determine the values, attitudes, and ways of behaving that define masculinity for specific clients and be sensitive to the fact that men who more strongly adhere to traditional male gender role norms might be more anxious than others about the process of seeking help (Good et al. 2005; Philpot 2001; Pollack and Levant 1998). Because men are generally ambivalent about seeking help for behavioral health problems, it is useful for clinicians to understand the circumstances that prompted a given man's help-seeking behavior. “Why are you here now?” and “For help with what problem?” are useful questions the clinician can ask when beginning the screening and assessment process. Treatment Improvement Protocol (TIP) 35, Enhancing Motivation for Change in Substance Abuse Treatment (Center for Substance Abuse Treatment [CSAT] 1999b) offers useful techniques for working with clients who are ambivalent about entering treatment.

Many clients are resistant to entering treatment; although traditional concepts of substance abuse treatment emphasize personal responsibility for change, it can be useful for clinicians to accept some responsibility for engaging male clients in the helping process and motivating them for change (Marini 2001; Miller and Rollnick 2002). Clinicians can creatively engage male clients by asking what a client hopes to change via treatment or what he hopes to gain by beginning treatment.

Men are often embarrassed or reluctant to self-disclose emotions, such as sadness or anxiety, so clinicians should consider acknowledging (e.g., through counselor self-disclosure) fears many men share about relationships, health, abandonment, career, and financial issues. Sometimes, self-disclosure is not warranted; therapists should not reveal personal information if they feel uncomfortable doing so or lack the training to do so properly (Forrest 2010). Clients' reactions to clinician self-disclosure will depend on their expectations. Counselors should try to gauge those expectations, as research suggests that clients who expect self-disclosure will respond by giving more information when their expectations are met (Dixon et al. 2001). Self-disclosure, when done in the best interests of the client, can help move sensitive topics into the open, thus giving clients permission to begin talking about them.

The engagement process can be conceptualized as a series of consecutive steps through which the client moves: screening, assessment, treatment planning, active treatment, and lastly, follow-up care (Good and Mintz 1990). Brooks (1998) suggests that, for men, clinicians assertively promote the need for substance abuse treatment and initiate the process one step at a time. The primary goal of each contact is to ensure that the client returns for his next appointment. Even if treatment is clearly indicated, it may be useful to first get the potential client to agree to an initial screening to determine whether further assessment is warranted. If it is, the next step is to get the potential client to agree to an initial assessment; next, to the completion of a comprehensive assessment; and finally, to a course of treatment.

Advice to Behavioral Health Clinicians: Helping Men Get Comfortable With Seeking Professional Assistance

- Establish rapport and trust with the client from the start.
- Male clients may feel threatened by or uncomfortable with the help-seeking process, so consider spending some time initially talking with the client about neutral topics (e.g., his work or hobbies) before beginning screening and assessment.
- Understand, as much as possible, what set of circumstances prompted the help-seeking behavior. “Why are you here now?” and “For help with what problem?” are useful questions to ask when beginning the screening and assessment process.
- Creatively engage a male client in discussions of his life and situation.
- Consider acknowledging common fears related to relationships, health, abandonment, career, and financial issues.
- Conceptualize the engagement process as a series of steps in which the client moves from screening to assessment to treatment planning to active treatment to follow-up care.
- Men are typically socialized to be goal-directed and action-oriented: Try ending each screening or assessment session with a clear plan for what will happen next.
- Something concrete (e.g., a letter documenting attendance, a telephone call to arrange a session with a significant other) may facilitate compliance with the next step.
- It can be helpful to give men something to do to prepare for the next step, which can support their sense of confidence, control, and usefulness.

Men are typically socialized to be goal-directed and action-oriented (Pollack 1998a, b, 2001), so emphasizing the immediate goal of each step in the screening and assessment process can be helpful, as can ending each screening or assessment session with a clear plan for what comes next. Offering something tangible at the end of an initial contact can also help. Depending on the circumstances that led to the initial screening or assessment session, something concrete (e.g., a letter of attendance, a telephone call to arrange a session with a significant other) can facilitate compliance with the next step. Giving men something to do to prepare for the next step supports their sense of confidence, control, and usefulness.

### Engagement Techniques for Men

Motivational techniques can help behavioral health clinicians engage men in the process of screening and assessment (Miller and Rollnick 2002). Emphasizing the importance of free choice, even when there appears to be none, generally supports men's need for autonomy. For example, even when men have legal mandates to seek treatment or are threatened with the loss of employment or a relationship, the decision to enter treatment can still be presented as voluntary. As much as a man might complain about his lack of choice, he often can still choose separation, legal sanction, or a job search over treatment. Men also can be offered choices about where and how screening and comprehensive assessment proceed; as much as possible, they should be offered choices and allowed to decide how the process will unfold. This process can be as simple as asking the man whether he would like to return next Tuesday or Wednesday or in the morning or afternoon. Emphasizing choices usually facilitates engagement. Similarly, although some treatment models emphasize assertive confrontation of denial, it may be useful, as Miller and Rollnick suggest, to avoid argument and circumvent resistance in a more subtle, less confrontational manner. For more on how to use Miller and Rollnick's approach to motivate clients with substance use disorders, see TIP 35 (CSAT 1999b). TIP 34, Brief Interventions and Brief Therapies for Substance Abuse (CSAT 1999a), discusses the use of brief strategic and solution-based therapies in substance abuse treatment, which also may be useful in motivating clients to address specific problems.

Advice to Behavioral Health Clinicians: Treatment Engagement Considerations With Men

- Emphasizing options and the importance of free choice, even when choices are limited, generally supports men's need for a sense of independence and autonomy.
- Confrontation about behavior and right/wrong issues almost always increases resistance. Avoid arguments and use a more subtle, less confrontational manner.
- Reframe coming to treatment as a success and a sign of strength and courage.
- Some men are uncomfortable expressing some or all emotions or have difficulty recognizing and labeling their emotions early in treatment. When discussing emotions, monitor intensity, and don't push clients to experience emotions that may overwhelm them. In some settings, talking while walking can decrease the intensity of direct eye contact and allow clients to dissipate excess energy.
- Some men find it easier to explore and discuss their problems using visual references, such as timelines, node-link maps, and genograms.

Directly acknowledging that men often have difficulty seeking assistance can be useful. Reframe comments about failure or weakness by defining help-seeking behavior as a sign of strength and courage. Early in the process, the clinician can highlight ways that adherence to traditional norms about help-seeking behavior may conflict with or undermine other gender norms about being gainfully employed, a good husband, and a good father.

Because men may be particularly uncomfortable with emotional expression or have difficulty identifying and understanding their own emotions early in treatment, the clinician should carefully monitor the emotional intensity of initial interactions, offering men time to compose themselves if needed. It may be useful to defer exploration of feelings until there is less anxiety about the helping process and a better working alliance. Avoiding competitive exchanges, comments, or questions that might provoke shame can likewise be helpful. In some settings, talking while walking can decrease the intensity of direct eye contact and allow clients to dissipate excess energy, which may help make some men more comfortable during initial sessions.

Some men find it easier to look at their problems through a concrete visual representation (Halpern 1997). A variety of visual mapping techniques are available for clinicians to use. Timelines (Suddaby and Landau 1998), node-link maps (Czuchry and Dansereau 2003; National Institute on Drug Abuse 1996), and genograms (DeMaria et al. 1999; McGoldrick et al. 2008), among others, can be useful in treatment (Dees and Dansereau 2000). Eco-maps, similar to genograms, are graphic portrayals of personal and family social relationships (Rempel et al. 2007). Node-link maps help clients see, in concrete terms, the consequences of life choices. Exhibit 3-1 provides an example of a node-link map to help a client address a cocaine addiction. For more on genograms, see TIP 39, Substance Abuse Treatment and Family Therapy (CSAT 2004b).

Exhibit 3-1 Node-Link Map

Exhibit 3-1: Node-Link Map

## Counselors' Gender: Some Considerations

Like ethnicity, race, religion, and culture, counselor and client gender can play a role in both the counselor's and client's experience of the therapeutic relationship. Gender colors the attitudes, feelings, beliefs, and interactions of both behavioral health counselors and clients. Therefore, it is important for treatment programs working with male clients to consider counselor gender. Both male and female counselors have their advantages, and programs need to consider the specific client as well as a range of other counselor- and program-related factors in assigning the best counselor for any given client. Counselors, too, need to be aware of gender dynamics and how they affect their practice.

Gender bias and stereotyping are among the most important issues that arise in substance treatment contexts with regard to the client's and counselor's gender. Other considerations that must be examined in the context of counseling men with substance abuse issues include the interplay between sexual orientation and gender, client preferences, the availability of male counselors, the appropriateness of raising the issue of gender with clients, and transference and countertransference issues.

### Overcoming Gender Bias and Stereotyping

Like ethnic or racial bias, gender stereotyping is often ingrained in the subconscious by socialization, and even the most well-meaning clinician may be affected by it. Everyone has expectations about how men should behave, and some of these expectations are stereotypes that tend to limit behavioral health clinicians' opportunities to provide the best possible treatment for their male clients.

How can clinicians overcome gender bias so that it does not negatively affect their work with men in substance abuse treatment? It is crucial that both male and female counselors explore their own biases and assumptions about men. Clinicians should ask themselves, “What is my first thought and immediate reaction to a male client who cries in a session? Do I directly or indirectly praise or encourage male clients who work long hours at the expense of their families? Do I assume that men respond to cognitive-behavioral therapy better than emotionally supportive therapy because men are rational?” Questions like these can help the clinician challenge deeply embedded assumptions and biases about men.

In general, questioning oneself helps overcome stereotypes and gender biases. When a male client walks into a clinician's office, the clinician should be able to adopt a stance of curiosity about his or her own understanding and the client's understanding of what it means for the client to be a man and how this identity is expressed in relation to his family, colleagues, friends, and the clinician. For example, many American men are raised to be independent and autonomous. Seeking or being mandated to treatment may feel like a weakness and affront to their sense of masculinity; however, such responses may not apply to a particular male client. Clinicians can inquire about such matters by saying, “I imagine that it may be difficult to ask for help because men are socialized to be strong and independent in our culture, but I am curious what it is like for you, specifically, to be here today.” The advice box below summarizes how both male and female counselors can address gender bias and stereotyping when working with male clients.

#### Raising the issue of gender with clients

Whether or not clients can choose to work with a male or a female counselor, asking about their preference during initial assessment is a way of raising the issue of gender. Clients can be asked not just about dates of previous treatment if applicable, but also about the gender of their primary counselors in those episodes. Counselors can then use this information to inquire about clients' past experiences with male and female counselors, what their preferences might be, and why. Exploring past counseling experiences and current preferences with regard to counselor gender is a nonjudgmental, empathetic way to let male clients know that their lived experience and preferences matter, even if it is not possible to match clients with their preferences. Johnson (2001) suggests including questions that address gender socialization and counselor gender preferences on the intake form and/or in the initial conversation with a male client.

### Client Transference Related to Counselor Gender

Transference is an unconscious process in which individuals assign attributes from important persons in their past to persons in their present lives. In behavioral health counseling, transference generally refers to attributes clients assign to their counselors. Countertransference reactions are the attributes counselors assign (from their histories) to their clients. Transference and countertransference are not inherently good or bad, but both can potentially disrupt the therapeutic process if not recognized and monitored.

Advice to Behavioral Health Clinicians: Addressing Gender Bias and Stereotyping While Working With Male Clients

##### Female counselors

- Explore your own gender biases and refrain from stereotyping men.
- Be curious and transparent. Make no assumptions about a client's lived experience based on gender.
- Don't be afraid to challenge male clients' psychological defenses and behavior in a nonjudgmental, nonshaming way.
- Take the client's preference for the gender of his counselor into consideration and match client and counselor when possible.
- Raise the issue of gender in the assessment phase and as a therapeutic issue.
- Explore your own countertransference issues in clinical supervision.

##### Male counselors

- Explore your own gender biases and refrain from stereotyping men.
- Be curious and transparent. Make no assumptions about a client's lived experience based on gender.
- Don't be afraid to be supportive and help male clients touch upon emotional content.
- Take the client's preference for the gender of the counselor into consideration and match client and counselor when possible.
- Raise the issue of gender in the assessment phase and as a therapeutic issue.
- Explore your own countertransference issues in clinical supervision.

One of the most difficult issues to address in any counseling context is the sexualized transference that is likely when a female counselor works with a heterosexual male client or a male counselor works with a gay male client. In therapy, the counselor invites the male client to be open to his feelings, be vulnerable, and engage in a kind of intimacy that may or may not be present in other relationships in that client's life. It is common and normal for the male client to feel emotional and/or sexual attraction for the counselor. Although this is a common occurrence, substance abuse treatment counselors may have received very little training in how to address client transference feelings, particularly sexual feelings. The following clinical scenario offers some options for addressing sexualized transference.

#### Case example: Hank and Jennifer

Hank is a married 32-year-old African American man with two young children. His drugs of choice were alcohol and marijuana; he entered treatment after his wife threatened to divorce him if he did not stop using. Hank describes his marital relationship as still shaky. He recently completed an intensive outpatient treatment program and was referred to individual counseling as part of his continuing care plan. He was given several counseling options and chose to make an appointment with Jennifer, a 28-year-old White American woman who has worked at the outpatient substance abuse clinic for 2 years. She is a lesbian who has lived with her domestic partner for 5 years.

She is a licensed substance abuse counselor. Jennifer has been seeing Hank on a weekly basis for 3 months when Hank discloses, during a session, that he feels a strong attraction to Jennifer. The following is a brief excerpt of the conversation that ensues.

Jennifer: Hank, I really appreciate the fact that you are risking being so open with me about your feelings toward me. I want you to know that your feelings are normal and a common experience for people who come to counseling. I know this is your first time in individual therapy, so I am wondering how it is for you to hear me say that what you are feeling is normal.

Hank: Well, it's kinda a relief. I thought I was going crazy or that I'm really weird. Especially since, well … you know … because you're gay. And you know I'm trying to make things right with my wife and I was worried that this meant that I don't love her anymore.

Jennifer: I understand your worry, but I want to reassure you again that it is very common for people to have all kinds of feelings, including sexual attraction, for their counselors. A good thing about these feelings coming up for you with me is that, because we have a professional relationship, there are boundaries that make it safe to talk about those feelings without acting on them.

Hank: Really?

Jennifer: Yes, really. In fact, think about how you have learned that you can talk about your desire to drink and how that helps you not act on your impulse to drink. You can talk about all sorts of feelings with me. I can help you learn how to experience and express those feelings in ways that support your goal to stay abstinent and that make things better with your wife and kids, instead of acting on your impulses in ways that aren't consistent with your values and what's important to you in your life.

Hank: I never thought about it that way. That's a relief.

Jennifer acknowledges Hank's attraction in a nonjudgmental way, establishes professional boundaries without shaming Hank, and uses his disclosure to reinforce the idea that feelings and impulses do not have to be acted out in negative ways, but can be expressed in ways that support his hopes and values. The key for the counselor is to understand that sexualized transference, which is not necessarily dependent on the gender or sexual identity of the counselor, is a common part of the counseling relationship and to view it as a potentially useful therapeutic opportunity to help the male client lessen the impact of shame in his life while modeling healthful ways of expressing and managing intense feelings.

#### Countertransference dynamics for men working with men

Scher (2005) states that “countertransference issues are more significant with men working with men than women working with men” (p. 317). He suggests that countertransference issues for male behavioral health clinicians may be more subtle when working with men than when working with women. He states that “when power elements surface, the male therapist goes into competitive mode and does not easily give the competitiveness up; once he does, he begins to feel closer and therefore more vulnerable to the client, which raises homophobic issues and necessitates a pulling back” (p. 317). So the male counselor faces a dilemma when working with male clients. How can he be supportive, model vulnerability, and develop the intimacy required to establish a strong therapeutic alliance without pulling away from the male client due to internalized homophobia? How can he do so without becoming competitive and dictating treatment goals and plans from the position of the expert who has the objective, rational, right answer?

Certainly, one of the most important things male counselors can do is address countertransference reactions in clinical supervision and consider them in their own practice. As discussed in Chapter 1, strong feelings of shame and inadequacy may arise whenever the male client consciously or subconsciously perceives that he is not living up to socially defined norms of male behavior, such as not asking for help and not being emotionally vulnerable. Male counselors also experience this dilemma when they open up to a clinical supervisor, and their experience of this vulnerability may be used to better understand clients' feelings. Any strong emotional attraction the male counselor might experience for a male client should also be monitored and addressed in clinical supervision. Due to prescribed masculine gender norms, male counselors might be reluctant to bring up feelings of warmth, love, and emotional attraction for male clients. Clinical supervisors should be nonjudgmental and create a safe relational space for male counselors to bring up any strong reactions they might have to their male clients.

If the male counselor is able to explore, with understanding and self-compassion, his own internalized beliefs about what it means to be a man, he will be in a much better position to help male clients challenge a story of masculinity that might not be their preferred way of being in the world. He will also be able to model a different kind of male behavior simply by being more open emotionally, less competitive and powerful, and working more collaboratively with clients.

#### Countertransference dynamics for women working with men

Female behavioral health clinicians may have, at one time or another, been ignored or belittled by men in authority; sexually harassed; and/or subjected to domestic violence, child abuse, or childhood sexual abuse. As a result, two of the most potent countertransference issues female counselors may experience in working with men are fear and unresolved anger. A female counselor may subconsciously fear that her male clients will ignore, judge, or belittle her, dominate or take over the therapy, or reject her efforts to help. One of the most difficult experiences women face in our society due to gender role socialization and culturally defined gender norms is a sense of being invisible. If a male client ignores the female counselor's recommendations or belittles the efficacy of the treatment, shame and inadequacy may be activated. A female counselor's subconscious anger may surface in the therapeutic relationship as cynicism, rejection of the client's ideas about what works best for him, or being judgmental. Female counselors may also be sexually attracted to male clients. Such feelings should be normalized and addressed in clinical supervision, where supervisors can address gender differences between themselves and their supervisees to help them understand countertransference toward male clients.

Due to gender socialization, some female counselors tend to defer to the male client's authority and his perception of his situation. Carlson (1981) suggests that “deference to male thinking, again reinforcing the traditional sex role for both, rarely assists the client in considering alternatives to his perception. Instead, it may only help to avoid the real problems and the potential for his growth” (p. 230). This can be a particularly challenging situation for female counselors in predominantly male substance abuse treatment programs. The female counselor must walk the line between being supportive and accepting and being willing to gently challenge the male client's psychological defenses, such as denial and minimization of the reality that substance abuse is interfering with his life and relationships.

#### Case example: Clinical team discusses male counselor/male client interaction

This behavioral health team consists of six clinicians (Jim, Larry, Lillian, Jason, Mary, and Kristen) and the clinical supervisor, Ken. The team is part of an intensive outpatient substance abuse treatment program at a major metropolitan hospital, which provides group therapy 5 days a week and individual counseling sessions twice a week. It is a mixed-gender program, but there is one women's and one men's group each week.

Jim brings up a clinical situation in group supervision. He has been assigned as the primary counselor for Kurt, a 45-year old bank executive who was referred to treatment through his company's employee assistance program. Kurt had been involved in derivative trading and a series of high risk mortgages. He had been a heavy drinker most of his adult life; because of the stress of the economic downturn and his bank teetering on the brink of bankruptcy, Kurt has been getting drunk three to four times a week and recently started taking tranquilizers to deal with his anxiety. Jim states that this is Kurt's first experience in counseling or treatment and that he is very resistant to Jim's recommendation to attend Alcoholics Anonymous (AA) meetings as part of his continuing care plan. The following discussion ensues.

Jim: This guy really irritates me. I've been clean and sober for 20 years and he thinks he is such a hot shot executive. Every time I try to suggest something that might help him stay away from the booze and the pills, he comes at me with some story about how I don't have a clue about what kind of stress he is under and that he knows what works for him … after all, he made it all the way up the corporate ladder to where he is today. I want to talk about whether or not we should consider shifting Kurt to another counselor. Maybe Mary or Kristen or Lillian could make more headway with him.

Ken: What makes you think that it might be better for Kurt to work with a woman?

Jim: Well, he seems to be more relaxed in the “Feelings Group” when Kristen is co-leading. And I think he really pushes my buttons. He reminds me of my older brother who was a varsity football player and won all kinds of awards. I hated football and was more interested in playing guitar in a local rock band. My father kept harping on me about how being in a rock band was for sissies. Now that I am talking this through, it seems to me that Kurt probably feels the same kind of shame about not being a real man because he was forced to come to treatment. Asking for help was not something that was real big in my own family.

Ken: Jim, I really appreciate your self-awareness here. It sounds like you are even beginning to feel less irritated and more compassionate toward Kurt.

Jim: Yeah, I guess so … but I don't know how to not react so strongly when Kurt gets so defensive.

Ken: Well, I am wondering if you would be interested in briefly role-playing with Kristen. We could get the woman's perspective on how to challenge Kurt's defenses in a nonthreatening, noncompetitive way. What do you think?

Jim: Well, I feel a little embarrassed about being in the spotlight.

Ken: I can imagine. I am wondering if that's some of your own fear about being vulnerable and thinking that because you're a guy, you always have to have all the answers.

Jim: You know me too well. Yeah, let's do it.

Ken sets up a roleplay in which Kristen plays counselor and Jim plays Kurt. Kristen is instructed to challenge Kurt's competitive behavior in a nonjudgmental, nonshaming way by pointing out the behavior and then asking, “What were the different expectations for boys and girls in your family?”

This question begins a conversation about gender roles and expectations for Jim as the client. Inviting Kristen to take on the role of counselor allows all participants to indirectly challenge their own gender stereotypes and biases. By the end of the roleplay, Jim decides that he can continue to work with Kurt, feels a deeper appreciation for Kurt's strategy of competitiveness as a way to hide his shame, and experiences renewed confidence for challenging Kurt's behavior in a nonjudgmental way. He leaves the team meeting feeling reassured that he can ask his female colleagues for help with countertransference.

### Advantages of Female Behavioral Health Counselors in All-Male Settings

The reality in most behavioral health clinical settings is that female counselors outnumber male counselors, and this disparity is even more striking when considering that male clients in substance abuse treatment significantly outnumber female clients (Lyme et al. 2008). Even in criminal justice settings, where the client population is typically all male, there are more female counselors than men (Ewing 2001).

Both male and female medical patients talk more and provide more relevant information to female physicians (Bertakis 2009; Bertakis et al. 2003; Hall and Roter 2002). However, two studies (Farber 2003; Farber and Hall 2002) found that gender did not predict disclosure among therapy patients. A small study (107 patients, 75 percent male) of a Dutch population (Jonker et al. 2000) found that men in substance abuse treatment preferred female counselors (64.5 percent) and that most (58 percent) thought counselor gender played an important role in their treatment. However, when patients were asked to describe ideal characteristics for male and female therapists, those they listed were identical.

Men may be more comfortable with female counselors for any number of reasons: they may feel more comfortable showing their weakness to female therapists, who they believe are less likely to judge them for their failures, real or imagined; they may believe that women are more sensitive and better able to address emotional problems; or they may have had negative experiences with male counselors in the past (Johnson 2001). Some of these perceptions are based on real differences between common male and female counseling styles. Compared with male clinicians, female clinicians typically are more open to discussing relational issues and focusing on underlying process issues during treatment (Miller 1984). This approach may be helpful for some men, who generally tend to have difficulty dealing with their emotions in therapy (Levant 1995; Pollack 1994). Among physicians, women provide more counseling but men are more likely to address substance abuse (Bertakis et al. 2003).

Another benefit to having female behavioral health service providers in facilities serving all-male populations is that they can model healthy male–female relationships for clients. Teamwork, cofacilitation of counseling, and collaborative working relationships between male and female staff members are of benefit to both the clinical team and clients because they provide positive role models for gender cooperation and communication. If clients see men and women interacting in healthy relationships with clear, nonsexist communication, they are likely to learn how men and women should act together.

### Potential Challenges for Female Counselors in All-Male Settings

Female clinicians who work with men do face certain challenges. Each client, whether male or female, brings a set of individual experiences as well as a unique cultural background into the client–counselor relationship that will influence how that client responds to a counselor. For example, some male clients may see the male counselors as the real therapists having the real power in the organization, and may not allow their female counselors the same authority, power, or credibility. Some men have difficulty hearing their female counselors, which likely has to do with differences in how men and women communicate. Also, some men are not used to communicating openly with women.

Behavioral health programs need to be sensitive to the reality that some men who may be antagonistic toward or biased against women in positions of authority may not be able to form a healthy therapeutic alliance with female counselors. Rather than looking for a scapegoat or blaming the client for this, the institution should work with the client to devise a solution that will most benefit him in his recovery from substance abuse. In such cases, it may be best to pair the client with a male counselor.

### Advantages of Male Behavioral Health Counselors in All-Male Settings

Men tend to address concrete tasks more readily with male behavioral health counselors, which may work more effectively in a treatment setting that uses task-oriented brief therapy, solution-focused techniques, and motivational interviewing (Lyme et al. 2008); see the “Enhancing Motivation” section in Chapter 5 of this TIP for more information. Some literature supports the theory that men, particularly those from certain cultural backgrounds, disclose more thoroughly to other men. For instance, one study showed that Hispanic/Latino men were more willing to report risk-taking behavior to men than to women, and to older men than to younger men (Wilson et al. 2002).

There are many potential benefits to having all-male group sessions, and a program typically needs male counselors to run these. Some well-known treatment centers, such as the Betty Ford Center and the Hazelden Clinic, will allow only male counselors to work with all-male treatment groups (Powell 2003).

### Potential Challenges for Male Behavioral Health Counselors in All-Male Settings

Problems can arise when men alone work as behavioral health clinicians in all-male settings. Male clinicians' biases and sexism can reinforce negative male communication patterns. Many patients seeking treatment prefer female counselors, so an all-male staff can greatly limit the choices and potential treatment of clients who have such a preference. Male counselors are themselves subject to gender role strain and may have difficulty seeing clients in terms of individual or family pathology or as struggling with cultural issues, such as how to be a husband and father (Silverstein et al. 2002). Male clinicians and supervisors working with men who are gay need to be aware of their own biases, countertransference, and level of awareness of gay development and gay culture (Frost 1998).

### Recruiting Male Behavioral Health Counselors

The first step for administrators in behavioral health settings assembling a trained, gender-sensitive male treatment staff is to understand their current staff makeup and the pool of providers from which they can expect to draw. The Substance Abuse and Mental Health Services Administration's (SAMHSA's) National Treatment Improvement Evaluation Study (Ewing 2001) examined staff members in treatment facilities that received SAMHSA funding. More than 800 counselors responded to the questionnaire. A majority of the counselors in each treatment setting (i.e., methadone, outpatient, short-term residential, long-term residential, and corrections) were women. In a larger study, Mulvey and colleagues (2003) used data from the retrospective study of treatment professionals to gain a profile analysis of the workforce within the substance abuse treatment field. Demographic information from 3,267 participants demonstrated that most treatment professionals were White (84.5 percent) and middle-aged (between 40 and 55 years of age), and slightly more were female (50.5 percent) than male (49.5 percent). Further, it was noted that most professionals remain in the field for a considerable period of time and that approximately 80 percent had earned a bachelor's or higher education degree. Most professionals were licensed or certified and provided treatment services to clients with racial and ethnic backgrounds different from their own.

It generally has been assumed that most clinical—and especially medical—education addressed men's issues to the detriment of women's issues. However, the 2003 SAMHSA Strategic Planning Initiative indicated that coverage of issues specific to men and substance abuse was lacking in most medical education programs (Haack and Adger 2002). As part of the 2003 SAMHSA initiative, training in substance abuse treatment, including men's issues, became a mandatory part of all medical education. This project is a three-way collaboration involving SAMHSA, the Health Resources and Services Administration (HRSA), and the Association for Medical Education and Research in Substance Abuse (AMERSA). SAMHSA and HRSA fund the project, which is administered by AMERSA. The project is known as “Project Mainstream.”

All clients, regardless of gender, age, or culture, should have treatment tailored to their needs. Although a specialized credential for clinicians whose patients are mostly or all male may not be necessary, the consensus panel recommends that ongoing training be provided to all clinicians in the substance abuse field concerning the unique issues of both men and women.

The number of female counselors is disproportional to the predominantly male client population seeking substance abuse treatment (Ewing 2001; Mulvey et al. 2003). Clinical centers staffed with both men and women of varying ages are better equipped to treat all clients. Agencies not committed to staff development, training, fair practices, and reasonable reimbursement can have problems in recruiting efforts, regardless of gender issues.

Centers that need more male staff members may have to develop them from the ground up. A variety of distance learning and local certification resources are available, and cultivating talented counselors from among the many individuals in recovery who join the field may be an appropriate avenue for many agencies. For instance, SAMHSA has established 14 regional Addiction Technology Transfer Centers (ATTCs) along with a national center dedicated to identifying and advancing opportunities for substance abuse treatment, upgrading the skills of practitioners and health professionals, and disseminating the latest science to the treatment community. The ATTC Network Web site offers more information on ATTCs (http://www.nattc.org).

## Counseling Men Who Have Difficulty Accessing or Expressing Emotions

A significant number of men participating in substance abuse treatment and other behavioral health services have difficulty accessing or expressing emotions (Evren et al. 2008). These deficits can range from a profound absence of any emotion (sometimes referred to as alexithymia or being emotionally frozen) to a more common difficulty in recognizing and expressing specific emotions, such as anger, sadness, or shame. Sometimes, difficulty in handling emotions is a symptom of a mental illness, such as Asperger's disorder, social anxiety disorder, or obsessive–compulsive disorder. Other times, it may result from transient or chronic stress, profound loss, or other environmental factors. For others still, difficulty with emotions may be a personality trait that has been with the individual since early childhood. All of these problems are likely to be exacerbated by substance use as a strategy for coping with unpleasant emotional states; finding new, positive strategies for understanding and expressing emotions is often necessary for a man's recovery from substance abuse (Holahan et al. 2001).

Some of the features of deficits in emotional expression include:

- Difficulty coping with situations in which emotions that the client has disavowed are pervasive (e.g., sadness at a funeral; tenderness at seeing a grandchild for the first time).
- Being dismissive of certain emotions (“anger is worthless”) or people who express emotions (“scared people are chumps”).
- Channeling a difficult emotion into another emotion (e.g., expressing fear as anger).
- Fearing that emotional expression will result in losing control (“if I start crying, I won't be able to stop”) or being overwhelmed (“if I feel my shame, I'll sink into nothingness; I won't exist anymore”).
- Projecting emotions onto others (e.g., assigning an emotion that is disavowed in oneself to others).
- Being very uncomfortable when someone expresses an emotion that is difficult to experience (e.g., being uncomfortable in the presence of someone expressing anger).

### Case Example: Jack

Jack is a 51-year old electrical engineer and computer software designer who recently completed the intensive phase of outpatient substance abuse treatment and has been referred to an ongoing therapy group for clients in recovery. His primary therapist in the intensive outpatient program felt the group would help Jack get in touch with his feelings. Jack readily acknowledges that he is a logical guy who sees emotions as having little utility, is uncomfortable around others who easily express emotions, and recognizes that his lack of emotionality has been a barrier in relationships. In his initial interview with the group leader, Jack comments that a primary reason for his heavy alcohol consumption (which began in high school) was that he felt more comfortable relating to others after drinking. He also recognizes that he was drawn to his occupation because it allows him to spend large amounts of time working alone and that he becomes uncomfortable in social and work situations when he cannot drink. In treatment, he found emotional expression in an all-male group difficult, and he is very apprehensive about being in a mixed-gender group now. He offered his primary counselor numerous reasons for not attending the outpatient group, but the counselor insisted that the experience would be good for him. He finally agreed to come for 12 visits (3 months). The following advice box gives some tips for Jack's counselor.

Advice to Behavioral Health Clinicians: Addressing Male Clients Who Have Deficits in Emotional Expression

- Clients who emphasize rationality over emotionality often respond to psychoeducational efforts, which can reduce problems related to feeling and expressing emotions for men (Levant et al. 2009). Learning about feelings is a first step for patients like Jack in addressing emotionally loaded issues.
- Work with these men during group and in individual sessions to apply feeling words to their internal/physical experience.
- Help the client identify emotions that are more comfortable for him (e.g., being scared) and support his efforts to manage the emotions that are more readily available first.
- Intervene and support him if other clients in the group shame or strongly confront his inability to express certain emotions.
- Help the client set goals for his group participation, particularly in terms of learning about emotions and how to express them to others.
- Work with him to develop self-grounding techniques for use when he becomes anxious in the presence of others who are expressing powerful emotions.
- Provide homework assignments to help him express his emotions within a highly structured context (e.g., through expressive writing assignments, which have been found to decrease emotional distress for men with restrictive emotionality [Wong et al. 2006]).

### Anger Management

Anger is a common problem for men with substance use disorders and can be exacerbated by the stress of early recovery. Because of men's socialization, anger is one of the only emotions that many men feel comfortable expressing—thus, they often use it to cover up emotions (e.g., fear, grief, sadness) that they feel inhibited about expressing (Lyme et al. 2008).

A high level of anger, particularly trait anger, in men has been associated with substance use disorders and physical aggression (Awalt et al. 1999; Giancola 2002b; Tafrate et al. 2002; Tivis et al. 1998). Trait anger refers to an individual's disposition to experience anger in different situations, whereas state anger is the magnitude of the anger felt at a given time. According to a review of the literature, high trait anger is associated with a tendency to experience anger more frequently, more intensely, and for a longer period of time (Parrott and Zeichner 2002). The effects of alcohol on male aggression are most prominent in those who have moderate—as opposed to low—levels of trait anger (Parrott and Zeichner 2002).

Men with anger problems are more prone to relapse to substance use (Kirby et al. 1995; McKay et al. 1995). A few cognitive–behavioral interventions have been shown to be effective in reducing anger in men who abuse substances (Awalt et al. 1997; Reilly and Shopshire 2000). Strategies used in one study to help subjects control their anger included the use of timeout, cognitive restructuring, conflict resolution, and relaxation training (Reilly and Shopshire 2000). Fernandez and Scott (2009) evaluated a 4-week-long cognitive–behavioral intervention for people in substance abuse treatment that was delivered in gender-specific groups; although the intervention had a high level of attrition (32 of 58 left before completion), it did reduce anger, especially trait anger.

Motivational enhancement therapy or motivational interviewing may be even more effective than cognitive–behavioral approaches in reducing substance use for men with a high level of anger. Researchers analyzing data from the Matching Alcoholism Treatments to Client Heterogeneity Project found that, in general, clients who had high levels of anger did significantly better (in terms of days sober and drinks per drinking day) if they received motivational enhancement therapy rather than 12-Step facilitation or cognitive–behavioral therapy, but that the opposite held true for clients with low levels of anger (Stout et al. 2003). Karno and Longabaugh (2004), looking at the same data, however, concluded that what was more important than the type of treatment received was the level of counselor directiveness; they determined that clients who had high levels of anger did significantly better with counselors who were less directive (as the motivational enhancement counselors were).

SAMHSA has produced an anger management curriculum with an accompanying client workbook that provides a manualized 12-week group treatment for use in substance abuse treatment settings (Reilly and Shopshire 2002). Exhibit 3-2 outlines some techniques used in this anger management intervention.

Exhibit 3-2 Anger Management Counseling Techniques

The main goals of anger management are to stop violence or the threat of violence and to teach clients ways to recognize and control their level of anger. There is no one correct way to conduct anger management counseling, but most interventions involve:

- Breathing and relaxation techniques for managing the physiological components of anger.
- Cognitive restructuring to make clients aware of their self-talk while helping them actively stop and revise their counterproductive thought processes.
- Taking time out by leaving an intense situation for several minutes to cool off.
- Introducing clients to the basics of assertiveness training and conflict resolution.
- Helping clients examine how anger and other emotions were displayed in their families and how the messages they received in the past affect them today.

Given the nature of the topic, anger management counseling should only be conducted by trained clinicians. At the start of the first session, the clinician should explain to the group any policies on safety, confidentiality, homework assignments, absences and cancellations, time outs, and relapses.

SAMHSA curricula on anger management are available in two volumes—a therapy manual and a participant workbook—and can be ordered from the SAMHSA Store (http://store.samhsa.gov) or downloaded from SAMHSA's Knowledge Application Program Web site (http://kap.samhsa.gov/products/manuals/index.htm).

Source: Reilly and Shopshire 2002. Adapted from material in the public domain.

### Learning To Nurture and To Avoid Violence

Many men with substance use disorders need to learn nurturing skills in their roles as husbands and fathers. Behavioral health counselors can teach and model affirming, caring, nurturing, forgiving, and having patience. Emotional vulnerability is critical if men are to be nurturing, loving, and caring husbands and fathers; it is important in many men's recovery. For example, the 12 Steps of AA address vulnerability and openness to others. Counselors can suggest that men express vulnerability by engaging in nonstereotypical activities (e.g., creating art, poetry, or music; performing community service) instead of stereotypically competitive male activities like sports and work. Clinicians can also help men identify sports that they enjoy that promote cooperation, bonding, and commitment rather than extreme competition and violence.

For many men, service is another essential part of recovery from substance abuse. Men who participate in mutual-help groups can be encouraged to engage in service activities related to those groups, and others can seek service opportunities in their communities or religious institutions, or with national or international groups. Service activities can be matched to men's interests and skills. For example, men in building trades can work with Habitat for Humanity; men who like to cook can help prepare soup kitchen meals. Counselors should be sensitive to the kinds of service that would be most rewarding and therapeutic for the client and should not assume that all clients will benefit therapeutically from service work.

### Learning To Cope With Rejection and Loss

Some male clients may need to learn how to accept being told “no.” Consider this scenario: A man is at a social hour after work and asks a woman at the party out on a date. She is not interested and politely says “no” to him. He feels disappointed and either becomes more aggressive with her or returns to the bar for a pick-me-up to restore his ego. It is important for him to hear “no” not as a rejection of who he is but as the result of other factors (e.g., the woman's interest in someone else). This insight could avert a relapse trigger for the client. The counselor may need to talk about and model for the client how to treat women with respect: taking “no” as an acceptable answer, giving women the power to accept or decline his invitation without intimidation, and experiencing her decision without it leading to substance use.

A man who is new to recovery may hear family members telling him “No, I won't lend you my car” as an expression of doubt concerning his recovery. He needs to consider that there may be other reasons for not lending him the vehicle and, in any case, it does not reflect who he is today; it may take time for others to see that he has changed. There are many such situations, and men in recovery need to understand that being denied something is not a reflection of their own self-worth.

Providers can introduce men to rituals that will help them deal with negative feelings, such as grief and fear, in a positive manner. Some examples include rituals for expressing grief, being vulnerable in the presence of other men, managing disagreements, and celebrating successes. Men can also observe the value of rituals in 12-Step programs, such as AA and Narcotics Anonymous.

## Counseling Men Who Feel Excessive Shame

Stigma and shame are strong obstacles to men's seeking help, and research shows that men in substance abuse treatment often rate their level of shame as high (Simons and Giorgio 2008). Many men with substance use disorders and their families “ignore prevention messages, avoid treatment, [and] endure suffering and risk death daily for the simplest of reasons: They're ashamed” (McMillin 1995, p. 3).

Social stigma tied to substance abuse, co-occurring disorders, other behavioral health problems, failure to meet society's expectations, and other problems can cause intense feelings of shame among men. Shame, in turn, can cause men to avoid needed treatment and can cause their families and friends to deny a man's substance use problem or try to control or cure him (Krugman 1995; McMillin 1995; Pollack and Levant 1998). Shame can also be a major impediment to growth in recovery. It can inhibit a man from looking inward, self-assessing, or experiencing personal deficits, resulting in white-knuckle abstinence and high risk of relapse.

Different men will react differently to shame, and not all men in treatment will experience it (although it is very common). When clinicians are uncertain about a client's degree or sources of shame, they can use an assessment instrument (see Chapter 2), and if the client is resistant to the notion that shame is affecting him, the clinician can share assessment results with him. For some men, shame can be an impetus for behavior change, whereas for others, it may impede change by fueling a desire to escape from the feeling rather than deal with its cause. Others respond to shame with secrecy, anger, denial, and/or hopelessness. Both Lewis (1971) and Scheff (1987) observe that some men externalize—holding others responsible for their actions—to shield themselves from experiencing shame.

A client's cultural orientation may also affect how he responds to shame. Anthropologists have proposed that certain cultures are shame based whereas others are guilt based; for example, for men from many Asian cultures, shame may be an even more significant feeling than for men from European cultures. There are also cultural differences in how individuals are expected to respond to shame. In some cultures, a man may be expected to publicly demonstrate his shame; in other cultures, a man may be expected to strike out in revenge at whomever caused him to feel shame.

Stigma is different from shame; it results from social attitudes that label certain people, behaviors, or attitudes as disgraceful or socially unacceptable. Crocker and Major (1989) found that people experiencing stigma:

- Frequently experience prejudice and discrimination.
- Feel that their social identity is devalued.
- Are aware that they are being stereotyped or worry that their behavior may be seen as stereotypical.
- Feel unjustly criticized or feel uncertain about the fairness of others' criticism.

Cultural stigma can produce shame in many men with substance use disorders. Men who break gender norms, for example, can be subjected to stigma and experience shame as a result. Eisler (1995) describes gender role stress for men, which can result when a man feels that he has transgressed traditional gender norms. This stress can lead to shame if he perceives that he has violated the norms of a social group or failed to live up to the group's expectations for appropriately masculine behavior.

Substance abuse can lead to behaviors or situations that a man might find shameful or stigmatizing, and many of these relate to a failure to meet prescribed gender roles. Because of substance abuse, a client may have failed to support his family, lost an important job, or experienced detriments to his sexual performance or alterations in his pattern of sexual behavior. Medical conditions, such as HIV/AIDS and certain disabilities (especially physical), are also often stigmatized, as are lack of employment and homelessness; Nonn (2007) notes that men who are homeless or have low socioeconomic status have been “stripped of everything that qualifies a man for full participation in society” and thus belong to a shamed group (p. 282). Sources of stigma are discussed in greater detail later in this chapter.

### Interventions for Shame

In many ways, behavioral health clinicians are already addressing client shame (whether the client is male or female). Mutual-help group and modern substance abuse treatment processes both begin with a fundamental anti-shame message. A major reason for educating clients about the disease model of substance use disorders and their psychological, physiological, and natural histories is to help them overcome the shame they may have experienced in believing their illness to be a personal or moral failing. Clients also benefit from psychoeducation about shame and stigma. In mutual-help groups, the camaraderie of working with others to overcome the effects of substance abuse can be a powerful force for replacing shame with acceptance. Clinicians who are in recovery can also help eliminate the shame of having a substance use disorder by serving as powerful role models for recovering people learning to accept their disorder.

Other interventions for shame are also already in use in most clinical situations. The most important way to help a client who is experiencing significant amounts of shame (see “Case example: Harry”) is to build a strong therapeutic alliance and create an atmosphere of trust in which the client feels comfortable openly exploring the sources of his shame. After building an alliance and exploring sources of shame, clinicians can help clients develop a realistic (i.e., not false) sense of pride, as pride in oneself is a major counter to shame (Krugman 1998). Shame is likely to emerge in many interventions with men; clinicians should thus tailor treatment to avoid further shaming a client (Krugman 1998; Pollack 1998c).

### Case Example: Harry

Harry is a 46-year-old man in an intensive outpatient substance abuse treatment program who has had numerous struggles in group and is seen by some counselors as uncooperative. He has resisted attending AA, tends to monopolize the group with long-winded stories of his successes, is defensive when confronted in group, and has not bonded well with other clients. He is also often sarcastic to other clients, but when they return the sarcasm, he either gets angry or withdraws and won't participate in the group process. His behavior tends to alienate him from others, which increases his isolation in the program. In a recent group clinical supervision session, staff members discussed his case and concluded that shame motivates much of Harry's disruptive behavior in group settings and that directly confronting his behavior makes him more defensive. Tips for counseling a client like Harry are given in the following advice box.

## Counseling Men With Histories of Violence

Violence and the use/abuse of certain substances (particularly alcohol and stimulants) are associated in numerous studies in many different contexts (Friedman 1998). Although violent behavior is not the sole prerogative of men, research has consistently found that men are more physically aggressive than women (Giancola and Zeichner 1995) and are much more likely to commit violent acts. For some men, acting in a violent manner may be a way to define their masculinity. Whether this response is simply the result of cultural factors or is due in part to biological differences is a question beyond the scope of this TIP. What is relevant, however, is that behavioral health service providers who work with men must be able to address violent behaviors in a client's past and be prepared for violence in the present (both in and outside the treatment setting). This section addresses men's involvement in violent behaviors; for more information on treating the short- and long-term consequences of exposure to violence, see the trauma section in Chapter 4.

### Violence and Criminal Behavior

Some men may engage in criminal behavior as a way of showing adherence to a particular concept of masculine identity (Copes and Hochstetler 2003); others take risks that can make them the victims of violent crime for the same reasons (Thorn 2003). Men are more likely than women to be the perpetrators as well as the victims of violent crime. In 2006, men were more likely to be the victims of every type of violent crime except rape, sexual assault, and purse snatching. In that same year, 26.7 per 1,000 men ages 12 and older were victims of violent crimes, whereas 22.7 women per 1,000 were victims of violent crimes (U.S. Department of Justice [DOJ] 2008). More than 60 percent of people treated in emergency rooms in 1994 for injuries resulting from violence were male (Rand 1997). In the case of murder, 77 percent of all victims and 90 percent of all perpetrators were male (Catalano 2004). According to 2006 data, men were more than 3 times as likely to be violent offenders as women. When violent crimes were committed by a single offender, 78.3 percent of offenders were male (DOJ 2008). Throughout North America and Europe, women commit fewer than 1 in 10 assaults (United Nations Economic Commission for Europe 2004). However, men who commit assaults while intoxicated are also more likely than women who do so to become involved in the criminal justice system as a result, although whether or not this reflects an existing bias remains to be determined (Timko et al. 2009).

Advice to Behavioral Health Clinicians: Addressing Male Clients Who Are Disruptive in Group Settings Due to Excessive Shame

- Help the client positively bond with other group members and aid him in finding commonalities with them rather than seeing himself as different.
- Additional individual counseling is less likely to provoke shame and may be efficacious.
- In individual sessions, psychoeducation about shame and its effects can be helpful.
- Involve the client in a 12-Step program where he'll feel safer identifying with others.
- Gently intervene when the client becomes sarcastic with other group members, taking care to confront him in a nonshaming way.

Violent crime is also strongly linked with alcohol and drug use, with alcohol being the most commonly reported substance in cases of violent crime. In 2006, approximately 27.1 percent of victims of violent crimes reported that the offender was using illicit drugs (either alone or in combination with alcohol) at the time of the offense (DOJ 2008). Reports by violent offenders are similar, with 41 percent of those in jails, 38 percent of those in State prisons, and 20 percent of those in Federal prisons reporting that they were under the influence of alcohol at the time of offense (Greenfeld et al. 1998). People who abuse alcohol (whether determined by self-report or official data) are also more likely to commit property crimes (Andersson et al. 1999). In a Federal Government survey of State prisoners who were expecting a 1999 release, 83.9 percent tested positive for alcohol or drugs when they committed their offense, with 45.3 percent having used drugs at the time of the crime (Hughes et al. 2001).

Certain substances are more likely to be associated with violent behaviors than others, but there is little research on how many substances affect violent behavior. However, enough data exist to support a link between alcohol use or abuse and being a perpetrator or victim of violence, especially among men (Stuart 2005). For men who are career criminals, substance use can be as important as criminal activity in defining masculinity (Copes and Hochstetler 2003).

Although different theories have been proposed for why men commit violent crimes, it does seem clear that gender roles hinder criminal behavior in women and enable it in men. Substances of abuse, especially alcohol, also seem to aid in removing inhibitions against violent and criminal behavior (Streifel 1997). Researchers postulate that men may expect alcohol to make them more prone to violence while women do not—a theory supported by Kantor and Asdigian (1997), who found that men were more likely than women to believe that alcohol increased irritability and feelings of power over others.

Lisak (2001a) suggests that many men who perpetrate violence are themselves victims of violence, and that it “is therefore imperative to treat this underlying trauma” (p. 286). He notes that this process begins by demonstrating empathy for their pain, which helps these men feel their own past pain; being able to do so and to believe that they are worthy of sympathy is a first step toward empathizing with the pain of others.

To reduce violent behavior in men, many behavioral health service providers have used cognitive–behavioral therapies to help men understand how criminal thinking patterns and irrational beliefs contribute to violent behavior. These approaches, often modeled on the Oakland Men's Project, typically teach communication skills to help men address problems in a more constructive manner. They are described in more depth in TIP 44, Substance Abuse Treatment for Adults in the Criminal Justice System (CSAT 2005b).

Anger management is another useful adjunct for men trying to address violent behavior. Several studies show that many men with substance use disorders have high levels of anger (Awalt et al. 1999; Giancola 2002b; Parrott and Zeichner 2002; Reilly and Shopshire 2000; Tafrate et al. 2002). Anger can often lead to aggression and violence and can serve as a precipitant for relapse. Teaching men cognitive–behavioral strategies that help them manage their anger can reduce aggression and violence and possibly improve treatment outcomes (Reilly and Shopshire 2000).

SAMHSA has produced Anger Management for Substance Abuse and Mental Health Clients: A Cognitive Behavioral Therapy Manual (Reilly and Shopshire 2002) and the accompanying Anger Management for Substance Abuse and Mental Health Clients: Participant Workbook (Reilly et al. 2002), which detail an anger management intervention appropriate for substance abuse treatment settings. Interventions that address criminal thinking and improve communication skills may also prove useful in substance abuse treatment for men who have a history of violent criminal behavior. In particular, these approaches can help men understand how their substance use is related to criminal thinking patterns.

Providers should note that the experience of violence can have a dissociating quality, and remembering past violence (whether one is victim or perpetrator, although typically perpetrators have also been victims of violence) can be a painful and problematic experience. Providers need to be sensitive to the difficulties clients may face in addressing violence in their past. (See the following sections on violence and abuse.)

### Domestic Violence and Child Abuse

The relationship between domestic violence and substance abuse is well documented (Caetano et al. 2001; Chase et al. 2003; Chermack et al. 2000; Cohen et al. 2003; Easton et al. 2000; Schumacher et al. 2003; Stuart 2005). The use of certain substances (e.g., alcohol, cocaine, methamphetamine) is associated with increased domestic violence, whereas use of others (e.g., marijuana, opioids) is not (Cohen et al. 2003). Some estimates suggest that up to 60 percent of men seeking treatment for alcohol abuse have perpetrated partner violence (Chermack et al. 2000; O'Farrell et al. 2004; Schumacher et al. 2003). A DOJ survey found that more than half of both prison and jail inmates convicted of a violent crime against a current or former partner had been drinking or using drugs at the time of the offense (Greenfeld et al. 1998).

A survey conducted by the National Committee to Prevent Child Abuse found that up to 80 percent of child abuse cases are associated with the use of alcohol and/or drugs by the perpetrator (McCurdy and Daro 1994). Many individuals who abuse their children were themselves abused in childhood. The rate at which violence is transmitted across generations in the general population has been estimated at 30 to 40 percent (Egeland et al. 1988; Kaufman and Zigler 1993). These probabilities suggest that as many as 4 of every 10 children who observe or experience family violence are at increased risk for becoming involved in a violent relationship in adulthood, either as perpetrator or as victim.

Substance use is also associated with being the victim of domestic abuse for both men and women (Chase et al. 2003; Cohen et al. 2003; Cunradi et al. 2002; Miller et al. 1989; Weinsheimer et al. 2005). Other risk factors for both genders include being young, having a high number of relationship problems, and having high levels of emotional distress (Chase et al. 2003).

Violence between intimate partners tends to escalate in frequency and severity over time, much like patterns of substance abuse. Thus, identifying and intervening in domestic violence situations as early as possible is paramount. Staff members should understand relevant State and Federal laws regarding domestic violence and their duty to report. More information on the legal issues relating to domestic violence and duty to report can be found in TIP 25, Substance Abuse Treatment and Domestic Violence (CSAT 1997b), along with other valuable information on this topic. TIP 36, Substance Abuse Treatment for Persons With Child Abuse and Neglect Issues (CSAT 2000b), discusses child abuse and neglect issues for clients in treatment who have been abused as children and/or have abused their own children.

Relapse can be a particularly high risk time for domestic violence, although it is unclear which event (relapse or domestic violence) precipitates the other. Regardless of causality, both issues need to be addressed. In the midst of a relapse crisis, it can be easy for the counselor to decide to deal with the violence at a later date. Several complications arise, however, as a result. Not addressing the violent behavior may imply that it is not significant or important. It also invites the client to sweep the event under the rug and not address it at a later date. Not addressing the violence may also signal to other family members that the violent behavior should not be brought into the open and discussed. Additional material on addressing domestic violence in counseling is offered later in this section.

When issues like domestic violence or child abuse are discussed, all behavioral health clinicians should be aware of confidentiality laws and any exceptions to those laws that may apply in specific instances. Providers should also be aware of applicable Federal regulations (notably, the Confidentiality of Alcohol and Drug Abuse Patient Records laws contained in 42 CFR Part 2) and specific State regulations or laws (e.g., “Megan's Laws”). Appendix B in TIP 25 (CSAT 1997b) and Appendix B in TIP 36 (CSAT 2000b) provide detailed discussions of these topics. In addition, the SAMHSA (2004) publication, The Confidentiality of Alcohol and Drug Abuse Patient Records Regulation and the HIPAA Privacy Rule: Implications for Alcohol and Substance Abuse Programs discusses these regulations as well as Health Insurance Portability and Accountability Act regulations that affect confidentiality of patient records.

#### Men as victims of domestic violence

Although women are commonly perceived as the victims of domestic violence, the reality is that men can also be victimized by either male or female partners. In the National Violence Against Women Survey, 15.4 percent of men who lived with male partners and 7.7 percent of men who lived with female partners reported stalking, physical assault, and/or sexual assault by their partners (Tjaden and Thoennes 2000). Other studies, which contextualized domestic violence as family conflict rather than criminal behavior, report higher rates of female-on-male violence, although the types of violence perpetrated and the likelihood of it resulting in injury were inconsistent (George 2003). In a meta-analysis of physical aggression between opposite-sex partners, Archer (2002) found that men were more likely to cause injury to partners but that men still sustained one third of injuries resulting from such acts.

Studies of clients in substance abuse treatment have found high levels of intimate partner violence perpetrated by women against men.

Cohen and colleagues (2003) interviewed 1,016 men and women in treatment for methamphetamine dependence: 26.3 percent of men (compared with 63.2 percent of women) reported that their partners had threatened them, and 26.3 percent of men (compared with 80 percent of women) reported that their partners had been physically violent. In a study of 103 women with alcohol use disorder seeking couples-based outpatient treatment, women were more likely to report having committed serious violence toward their partners (50 percent) than having been victims of such violence (22 percent), although this was not the case in a study of women seeking individually based treatment for alcohol abuse (Chase et al. 2003). It should also be noted that unmarried intimate partners appear to be more likely to commit violent acts toward one another than married partners (Straus 1999).

Because stereotypes of masculinity (see Chapter 1) stress self-sufficiency and strength, men who have been abused by their partners may be even less willing to seek help than women. Additionally, there are fewer resources available for male victims of domestic violence than for female victims. The majority of domestic violence programs are designed for women, and many will not provide assistance to male victims; also, many men who are abused by their partners do not feel that the justice system will support them even if they do report the crime (McNeely et al. 2001). The problem is further complicated by traditional beliefs that men should be the head of the household and men's fear of ridicule for not filling that role; the shame men may feel at disclosing family violence is compounded by the shame of not being able to keep their partners under control (Straus 1999). Often, providers presume that men in treatment should be screened as potential abusers but not as victims of domestic abuse, especially when the man's partner is a woman (CSAT 1997b).

Limited data are available on the rates of intimate partner abuse among gay male couples: for example, the National Violence Against Women Survey (Tjaden and Thoennes 2000) found that men with male partners were twice as likely to experience domestic violence as men with female partners. Bartholomew and colleagues (2000) compared factors associated with partner abuse in heterosexual and gay couples, concluding that they were largely the same and that substance use played a significant role in both situations. In a review of 19 studies that examined partner violence in gay and lesbian couples, Burke and Follingstad (1999) only found 3 that gathered data from gay male couples and 1 that extrapolated data on rates of abuse for heterosexual men. Still, these limited studies suggest that men in same-sex relationships are at least as likely to experience violence from their partners as men in opposite-sex relationships.

#### Treatment and referral for domestic violence

For men who have a history of either perpetrating or being victimized by domestic violence, collaboration with and referrals to domestic violence intervention programs can facilitate their substance abuse treatment. At the same time, behavioral health service providers need to be aware that certain therapeutic interventions (particularly couples or family therapy) can increase the likelihood of further domestic violence and should not be used with clients who have such a history. In some States, standards for domestic violence treatment programs warn against couples counseling as an initial intervention, and some standards regulate what individual treatment improvements need to occur prior to any couples counseling. Interventions designed to reduce domestic violence without addressing substance abuse have proven to be minimally effective (Stuart 2005).

Counselors not specifically trained in treating domestic violence issues should refer clients to counselors qualified to treat these problems, either within their own behavioral health program or elsewhere in the community, and they should share pertinent information with domestic violence staff (as permitted by confidentiality rules) to ensure that both problems are addressed. Providers should not hesitate to leverage the criminal justice system to ensure that male batterers participate in domestic violence treatment.

When a clinician suspects that a man may be being abused by an intimate partner, he or she should address the problem in an individual counseling session emphasizing nonshaming support and education. Options for accessing help and potentially removing himself from the relationship should be discussed. Very few domestic violence programs or shelters exist for male clients, but in certain areas, there are programs to which clinicians can refer a man. The Battered Men Web site posts information on such programs (http://www.batteredmen.com).

Because of the close relationship between substance use/abuse and domestic violence, substance abuse treatment in and of itself may help reduce domestic violence for some clients (Stuart 2005). Behavioral couples therapy (also known as behavioral marital therapy) is a substance abuse treatment approach designed specifically to improve relationships while also increasing abstinence. O'Farrell and colleagues (2004) found that this therapy significantly reduced domestic violence (as measured by the Conflict Tactics Scale) and was effective up to 2 years after treatment for men with alcohol use disorder. Again, however, if the potential for a reoccurrence of domestic violence exists, caution should be exercised in implementing couples therapy. More information on this intervention can be found in Chapter 5, as well as in TIP 39 (CSAT 2004b).

### Sexual Violence

Sexual violence has long been associated with alcohol consumption. In one study, 75 percent of men who admitted to behavior that met legal definitions of rape acknowledged being under the influence of alcohol when they committed the act (Koss and Dinero 1988). Peugh and Belenko (2001) report that two thirds of incarcerated sex offenders either used substances at the time of their crime or had a history of substance abuse. Alcohol use is more common than illicit drug use among these men. Illicit drug use, however, is more common among offenders who victimize adults than those who target children. The consensus among researchers is that substance use does not cause sexual assault; rather, it contributes to the crime in other ways. Sex offenders also frequently have histories of victimization or co-occurring mental disorders or other behavioral health problems, which further complicate their treatment picture (Peugh and Belenko 2001). (See the sections later in this chapter on male survivors of adult or childhood sexual abuse.)

The vast majority of sex offenders are male. In 2006, 95.4 percent were male, whereas just 2.9 percent were female and 1.8 percent were of unknown gender (DOJ 2008). Among incarcerated sex offenders in 1994, 99.6 percent of an estimated 33,800 convicted rapists were male, as were 98.8 percent of the 54,300 people convicted of sexual assault (Greenfeld 1997).

Several studies have addressed the comorbidity of substance abuse and sexually abusive or violent behavior. Raymond and colleagues (1999) found that 60 percent of a group of 45 pedophiles had a lifetime prevalence of substance use disorders. In a similar sample size of adult sex offenders, McElroy and colleagues (1999) reported that 83 percent met criteria for a substance use disorder; these men also had high lifetime rates of co-occurring mental issues (e.g., mood and anxiety disorders).

Screening for and addressing patterns of sexual violence among clients in substance abuse treatment is imperative, but treatment of sexual violence requires specialized training, close clinical supervision by someone trained in sexual violence treatment, special programmatic constraints, and often, mandates for treatment from legal and criminal justice resources. Substance abuse counselors should be skilled in screening for sexual violence and knowledgeable of community resources for care. When possible, substance abuse programs should facilitate concurrent care for both substance use and sexual violence.

### Violent Behavior in Treatment

A man's violent behavior can interfere with his substance abuse treatment, and conversely, his substance abuse can interfere with interventions aimed at changing his violent behavior (Bennett 1995; CSAT 1997b). Clients should be informed upon entering a program what behaviors are acceptable and what consequences result from unacceptable behaviors (e.g., treatment termination, loss of privileges). The nature of a program's response depends on its ability to impose sanctions and its requirements to retain or not retain clients. Anger management techniques (see Chapter 5), which are used by many substance abuse treatment programs, can help reduce violent behavior and can have a number of positive secondary outcomes, such as helping clients reduce impulsive behavior and maintain self-control. Conflict resolution, cognitive restructuring, relaxation exercises, and other such techniques can help clients with their anger and aggressive impulses. Having a client take time out from individual or group therapy sessions if he feels increasing anger is also a useful intervention for deescalating violence. Substance abuse treatment programs are responsible for protecting the health and welfare of all clients and for monitoring potentially violent clients to ensure the safety of other clients in the program. Programs should have policies to guide staff in addressing situations in which one client's violent behavior might affect the welfare of others.

## Counseling Men About Sexual Issues

Sexuality and sexual behavior are intimately connected with gender identity for most men (regardless of their sexual orientation). Masculine norms that put a priority on success, self-reliance, and reliability all contribute to men's fear that sexual performance problems reflect negatively on their masculine identities.

Some men are more comfortable discussing sexual issues with a male counselor; others prefer doing so with a female counselor. Both male and female counselors can help male clients feel more comfortable with questions concerning sexual behavior. Male counselors can use self-disclosure and empathy to reduce the client's sense of isolation; female counselors can react positively to the client's disclosure of sexual fears and concerns, thus offering a positive and therapeutic experience.

### Substance Use and Sexuality

According to Braun-Harvey's (1997) review of the literature, compulsive sexual behavior is much more common among men than women. Limited research and clinical experience also show that sexual dependency (a term used to refer to a broad range of behaviors involving problems of sexual control and preoccupation that result in psychological distress) is more common among men who abuse substances than those who do not.

Using substances to lower one's inhibitions before and during sex is a widespread practice among youth in the United States, which often carries over into adulthood. As adults, some men might use alcohol to calm anxious feelings they may have about sexual performance (e.g., being able to achieve an erection or please a partner) or as an excuse for certain sexual behaviors that may otherwise be the source of intense guilt or shame. Other men use illicit drugs to control sexual response. For example, some individuals who use methamphetamine believe that it can prolong an erection and provide stamina for longer sessions of sexual activity. Stimulants (such as methamphetamine and cocaine) are also associated with intensified sexual thoughts, feelings, and fantasies (although very large doses can have the opposite effect). Some people use these substances only in sexual situations, while others seek sexual encounters because of the drug's effects.

Research with 464 men and women entering outpatient substance abuse treatment found that 55.3 percent of men who used cocaine as their primary substance of abuse and 85.3 percent of those who used methamphetamine reported that the drug increased their sex drive; by comparison, 11.1 and 55.6 percent of women, respectively, reported the same (Rawson et al. 2002). In the same study, 55.3 percent of men who primarily used cocaine and 76.5 who primarily used methamphetamine reported that the drugs made them obsessed with sex or made their sex drive abnormally high.

Crack cocaine has also been thought of as heightening sexual experiences, and cocaine has been viewed as affecting the sexual arousal areas of the brain (Angrist 1987). Men often report relapse as a result of wanting to experience sexual activity under the influence of the drug (Gottheil et al. 1998), and similar associations are found in those who use methamphetamine (Rawson et al. 2002; Washton 2009). Among gay men, methamphetamine use is also associated with a greater likelihood of engaging in impulsive sexual activity (Halkitis et al. 2009a; Semple et al. 2006). In treatment, counselor and client should engage in a therapeutic dialog regarding the relationship of stimulant use to sexuality; particularly for these clients, management of sexual desire should be incorporated into a relapse prevention program.

3,4-methylenedioxymethamphetamine (MDMA), also known as ecstasy, is another drug used to enhance sexual desire and satisfaction. In a study of 35 healthy individuals who used MDMA for recreational purposes, 20 of whom were men ages 21 to 48, more than 90 percent perceived that their sexual desire and satisfaction were moderately to profoundly increased by MDMA. However, despite its alleged enhancement of sexual desire and satisfaction, MDMA may impair sexual performance: orgasm was delayed but perceived as more intense, while erection was impaired in 40 percent of the men (Zemishlany et al. 2001).

### Substance Abuse and the Male Reproductive System

Substances of abuse can have a profound effect on men's reproductive health as well as their sexual functioning. Data are not available on the effects of many illicit drugs on men's reproductive health, but the use of alcohol is prevalent enough to delineate certain facts. Men who drink heavily increase their risk for both impotence and low sperm count. According to the literature, some studies have shown that even moderate alcohol consumption can decrease the production of sperm and alter its physical structure (Burke 1999; Nudell et al. 2002). Impotence may be reversible with the return of abstinence, but it can be persistent when chronic heavy drinking has contributed to neurological, endocrine, or vascular dysfunction (Burke 1999). Alcohol is known to affect the endocrine system, which regulates growth, reproduction, and other bodily functions. Alcohol use has also been linked to low testosterone, which can intensify levels of depression for men (Booth et al. 1999), and to altered levels of other reproductive hormones (Emanuele and Emanuele 2001).

Not only does chronic alcohol consumption affect a man's ability to impregnate his partner; it also influences his ability to produce healthy children (Emanuele and Emanuele 2001). In Klonoff-Cohen and colleagues' study (2003) of 221 couples with female infertility, increased risk of spontaneous miscarriage and failure to achieve a live birth were both linked with male alcohol use in the month before and during in vitro fertilization (a process in which a woman's eggs are fertilized in an artificial environment and then inserted into her uterus) or gamete intrafallopian transfer (a technique in which eggs and sperm are inserted directly into a woman's fallopian tubes, where fertilization may occur). In another study, male rats, whose reproductive systems are similar to those of human men, were treated with alcohol for 9 weeks prior to breeding. The alcohol significantly decreased the average weight of the resulting fetuses and increased the incidence of undersized offspring (Bielawski et al. 2002).

Other substances can also affect a man's fertility. Some studies have associated cigarette smoking with decreases in male fertility (Curtis et al. 1997; Nudell et al. 2002). Marijuana appears to decrease sperm density, motility, and morphology (Nudell et al. 2002); methadone decreases the amount of sperm ejaculated (GlaxoSmithKline 2005). Many men are not aware and should be informed that marijuana use has also been associated with increased rates of a number of male-specific cancers (e.g., prostate, testicular, penile) as well as a range of other health problems (see review by Pujazon-Zazik and Park 2009). Anabolic steroids, too, affect the male reproductive system in several ways, including producing testicular atrophy. Other substances, such as opioids, cocaine, and amphetamines, may decrease libido when taken in large doses (Nudell et al. 2002).

### Sexual Identity

Men trying to come to terms with a gay or bisexual identity often need to focus “on stigma and negative societal attitudes [and] coping mechanisms ranging from denial to nondisclosure” (Taylor 1999, p. 524). In a study on homosexual identification, Weinberg and Williams (1974) found a relationship between gay men's “worrying about exposure and anticipating sanctions” (p. 178) and “being publicly identified as a homosexual” (p. 9). This inhibition is sometimes associated with multiple health and substance use problems for gay men. For example, Cole and colleagues (1996) found that gay men who tested negative for HIV/AIDS and who were closeted had higher rates of cancer and moderately serious infectious diseases than those who were able to be open about their sexuality.

Some men may identify as heterosexual despite engaging in sex with other men. Such behavior may be a temporary or experimental stage, as might occur during adolescence or in the absence of female partners (e.g., in prison). Some men who identify as heterosexual may only have sex with men when under the influence of substances, either because they feel too much shame to do so when abstinent or because the substances impair their judgment; this causes them to feel shame afterward, when no longer under the influence. This can be a significant problem for some men in recovery who feel an added compulsion to use substances to escape feelings of intense shame associated with past sexual behavior or to feel able to express their sexuality.

Becoming comfortable identifying oneself as gay or bisexual is an important part of seeing oneself as part of a larger gay/bisexual community. Being a part of such a community can provide greater access to sources of emotional support that could combat feelings of marginalization due to heterosexism, which can otherwise contribute to distress and mental disorders among gay men (Meyer 1995). These feelings of distress, coupled with a lack of social support or ineffective coping skills, may lead to use of alcohol or drugs. If gay/bisexual men are able to see themselves as part of a larger gay/bisexual community, it may improve their self-esteem and thereby lessen their substance abuse. Some gay men feel considerably more comfortable in programs or treatment groups that are specifically organized to assist gay men, although such options are not available in all areas. Clinicians working with self-identified gay men in other treatment settings should speak with them to determine whether they wish to identify themselves as gay (i.e., be out) in the program.

Sexual orientation is sometimes misperceived as reflecting a person's masculinity, leading to assumptions that all gay or bisexual men are inherently feminine. This belief can result from simple misinformation or can be the product of homophobia. However, what is labeled as effeminate behavior has no real relation to sexual orientation. Gay/bisexual men may be very masculine; heterosexual men may act effeminate. Counselors should educate clients about sexual orientation and the fact that the degree of masculine or feminine behavior a person exhibits is not related to it.

A Provider's Introduction to Substance Abuse Treatment for Lesbian, Gay, Bisexual, and Transgender Individuals (CSAT 2001) contains more information on substance abuse treatment for gay and bisexual men.

### Sexual Performance and Sexual Dysfunction

Fracher and Kimmel (1987) identify the three most common sexual complaints of men seeking therapy—premature ejaculation, inhibited sexual desire, and erectile dysfunction—as issues of sexual performance. Although men often focus on physical symptoms when seeking assistance, Fracher and Kimmel note the importance of the response to the symptom (e.g., anxiety, depression, low self-esteem) that prompts men to seek help and that those responses result from men's failure to perform at the standard dictated by traditional masculine gender roles. To treat sexual dysfunction, they recommend addressing the client's beliefs about masculinity through “exploring and challenging the myths of male sexuality, modeling by the therapist of a different version of masculinity, giving permission to the patient to fail, and self-disclosure by the therapist of the doubts, fears of inadequacy, and other anxieties that all men experience” (p. 92).

Medications for male sexual dysfunction are now widely used. However, a man in recovery may be resistant to such medication—sometimes with good reason—as there have been some reports of abuse of medications like sildenafil (Viagra), especially among gay and bisexual men (Crosby and DiClemente 2004; Smith and Romanelli 2005). Abuse of sildenafil also appears to be more common among men who abuse other substances. Crosby and DiClemente (2004) found that in a sample of men who had sex with men, those who abused cocaine, MDMA, or alkyl nitrate inhalants were 2 to 3 times more likely (depending on the substance) to use nonprescription sildenafil than men who did not use them. Clients considering medication to improve sexual performance should be cautioned about the potential for abuse and other health risks.

### Sex and the Internet

Thanks to the Internet, millions of people can now easily access a wealth of information on just about every topic of interest and effortlessly talk with others despite great physical distance. However, this technology also enables people to find an “impersonal, detached sexual outlet” (Schwartz and Southern 2000, p. 128). Those who seek sexual partners and gratification over the Internet are engaged in what is often referred to as cybersex. They may be involved with a variety of partners in different ways. Some participants compulsively search for partners for hours, seeking to create various fantasy scenarios; others spend large sums of money on interactive pornography. Some men believe that cybersex allows them to engage in sexual activity with less anxiety.

Men are significantly more likely than women to engage in online sexual activities. In one large study (n=7,037) men were twice as likely as women to report engaging in online sexual activity to deal with stress (rather than as a distraction or for educational purposes); however, the same study found no significant difference in the number of men (10.5 percent) and women (4.9 percent) who reported a sexual addiction (Cooper et al. 2002). Schwartz and Southern (2000) linked compulsive online sexual activity with male substance abuse in a study of 40 people seeking treatment for problematic cybersex involvement: 73.7 percent of men (but just 42.9 percent of women) reported a substance abuse problem.

The investigation of compulsive online sexual activity is a relatively recent field of study, and screening and treatment approaches are still in development. Cooper and colleagues (2004) found that Internet users who spend more than 11 hours per week engaged in online sexual activity are also likely to score high on measures of sexual compulsivity, and the number of hours spent on such activity may be used as a simple screening question. Schwartz and Southern (2000) suggest that cognitive-behavioral approaches be used to change behaviors for men with a cybersex addiction. They also suggest additional therapies to treat other problems that may be at the root of such addiction (e.g., depression, trauma, conflicts in relationships, sexual dysfunction, conflict over sexual identity). Some substance abuse treatment programs now also offer treatment for sexual compulsivity and addiction, either as an integrated component of substance abuse treatment or as a separate therapeutic effort.

### Sex Trade Workers

Participating in the sex trade is typically not so much a sexual behavior as it is the product of economic necessity and should generally be considered in that light. Poverty may lead adult or adolescent men into prostitution or into exchanging sex for drugs, alcohol, or money.

Involvement in the sex trade (which, for men, typically involves sex with other men) appears to be more common among men who identify as gay or bisexual, but even men who identify as heterosexual may engage in sex with men for money. Prostitution also appears to be much more common among younger men, and a number of clients in treatment settings may have participated in the sex trade as juveniles. In a study of 358 men ages 19 to 35, all of whom identified as gay or bisexual and were HIV negative, 9.8 percent stated that they had engaged in juvenile prostitution (Ratner et al. 2003). Sex trade work also appears to be much more common among gay and bisexual men who inject drugs than among those who do not (Rietmeijer et al. 1998).

Some men choose prostitution primarily as a way to experiment sexually while earning extra money, not as an economic necessity. Cates and Markley (1992) compared a group of 15 young men who stated they were prostitutes by choice rather than necessity with 15 men from the same cohort who were not prostitutes; those prostituting by choice reported significantly more substance use than those uninvolved in prostitution. Men who had been prostitutes also reported more familial substance abuse.

### Rape and Sexual Abuse Among Adult Men

The sexual abuse of adult men is rare. According to DOJ estimates, only 0.2 out of every 1,000 men were victims of sexual abuse in 2003 compared with 1.5 out of every 1,000 women (Catalano 2004). A survey of 2,500 British men found that 2.9 percent had experienced nonconsensual sex as adults, although 5.4 percent reported having had nonconsensual sex as children (Coxell et al. 1999). In samples of self-identified gay and bisexual men, rates of adult and childhood sexual abuse are higher. Ratner and colleagues (2003) sampled 358 HIV-negative men who identified as gay or bisexual; of these, 14 percent reported childhood sexual abuse and 14.2 percent reported nonconsensual sex as adults (defined as being over the age of 14).

What little research exists into sexual assault among incarcerated men suggests that rates in this population are comparable to those found among women in the general population. There is wide variation in prevalence rates across studies because of differences in definitions of sexual assault, methods used to obtain data, and sample sizes. However, all studies imply that sexual assault in prison is significant. The Prison Rape Elimination Act of 2003 (P.L. 108-79) called for a comprehensive study of prison rape to more accurately determine the extent of sexual assault among incarcerated men (Gaes and Goldberg 2004; Thompson et al. 2008). The Just Detention site (http://www.justdetention.org) offers a resource guide for survivors of rape during incarceration as well as other information of use to survivors and their clinicians.

Because of high rates of HIV/AIDS and other sexually transmitted diseases in the prison population, men who have been raped while incarcerated run a high risk of contracting a sexually transmitted disease (Robertson 2003). Many prison institutions do not test for HIV/AIDS unless an incident report has been filed, but the majority of cases of sexual assault behind bars may go unreported (Gaes and Goldberg 2004; Robertson 2003). In addition to counseling, men in substance abuse treatment who state that they have been sexually assaulted (while incarcerated or not) should receive HIV/AIDS testing and counseling.

Given data on childhood and adult sexual abuse, the number of adult men who have been sexually abused at some point during their lifetimes may be significant, and especially so for men in substance abuse treatment. For example, Ouimette and colleagues (2000) assessed the physical and sexual abuse histories of 24,959 veterans (24,206 of whom were male) who had substance use disorders; 8 percent of the men had experienced sexual abuse during their lifetimes. Lifetime rates of sexual abuse were much higher for women in their study (49.4 percent), but both men and women with sexual abuse histories had similarly poor outcomes as measured 2 years later, even taking into account baseline functioning, co-occurring mental illnesses, and relevant demographic variables (Rosen et al. 2002a).

### Childhood Sexual Abuse

Rates of child abuse (of all types) are similar between the sexes, but the types of abuses endured differ. According to 2002 data from child protective service agencies across the United States, 48.1 percent of victims ages 17 and under were boys and 51.9 percent were girls (Administration for Children and Families [ACF] 2004). A more recent report shows that, among children reported to child protective services throughout the United States, 48.2 percent were boys and 51.5 percent were girls; in 0.3 percent of cases, the gender was unknown (U.S. Department of Health and Human Services [HHS], ACF 2009). A large-scale review by Trocme and colleagues (2001) of child maltreatment investigations in Canada found that 51 percent involved male children and that, among children over age 15, a greater number of investigations were substantiated involving boys (60 percent) than girls (42 percent) (Trocmé et al. 2001).

Girls under age 18 are about three times more likely than boys to experience sexual abuse, but boys are more likely than girls to experience emotional neglect or serious physical injury due to abuse (Sedlak and Broadhurst 1996). Self-reports from college students and general population surveys suggest that 10 to 20 percent of men were physically abused as children (Lisak 2001b). Boys are also more likely to die from maltreatment than girls of comparable age (ACF 2004).

Girls are more often sexually abused than boys, but male individuals are more likely to be sexually abused as children than as adults; the age at which a man is most likely to be a victim of sexual assault is 4 years old (Snyder 2000). Estimates as to the prevalence of sexual abuse of boys vary widely (Holmes and Slap 1998), but studies have found that between 8 and 29 percent of adult men have endured childhood sexual abuse (Gorey and Leslie 1997; Putnam 2003; Snyder 2000). Based on 16 cross-sectional studies of sexual abuse of children in North America (adjusted for sample size), Gorey and Leslie (1997) estimate that approximately 8 percent of adult men were childhood victims of sexual abuse.

Despite one fifth to one quarter of juvenile victims (ages 18 and under) of sexual assault being male, few providers screen for histories of sexual abuse among male clients. In a study of 179 mental health professionals, 82 percent reported that they rarely or never inquired about the sexual abuse histories of men receiving services; many were unaware of the extent of sexual abuse of male children, and most (69.2 percent) felt that they had received insufficient training to inquire about it (Lab et al. 2000). Male victims of childhood sexual abuse may be even less willing to report it than female victims (Holmes and Slap 1998)—especially if the perpetrator is an adult woman and the victim a male adolescent, as both the victim and society have a harder time recognizing such acts as abuse (Mathews 1996).

Sexual abuse in childhood is linked with increased rates of substance use and various other behavioral health problems, including mental illness, suicide attempts and completions, gender role confusion, and involvement in high risk sexual behaviors; it can also increase the likelihood that the individual will sexually abuse others (Dube et al. 2001; Holmes and Slap 1998; Zielinski 2009). Unfortunately, only after becoming involved in the criminal justice system do many adult men receive any assistance with their childhood sexual victimization (Mathews 1996).

A history of childhood sexual abuse can profoundly affect a male client's substance abuse treatment in adulthood. For instance, typical efforts to help men bond with other male clients in treatment may provoke significant anxiety, and the abused client may withdraw, appear angry or threatening to others, or act fearful and hesitant. Sexually charged humor may be misconstrued by such a client; even demonstrations by counselors (or clients) of being interested in or concerned about the client can be seen as similar to the interest shown by a sexual perpetrator. It is often difficult to identify a client with a history of sexual abuse, so routine physical exams that require a client to disrobe or that involve touching a client's genitalia must be conducted with respect and sensitivity for the man's privacy.

#### Case example: George

George is a 26-year old client in an inpatient substance abuse treatment program for men with co-occurring disorders. This is his first admission for substance abuse treatment, but he has, since early adolescence, been treated for various mental disorders, including depression, attention deficit hyperactivity disorder, panic disorder, and mixed personality disorder. Prior to entering treatment, he never told anyone that when he was 12, he was repeatedly sexually assaulted by a counselor at a camp for boys without fathers. In late adolescence, he questioned his sexual orientation and tried to resolve this dilemma by refraining from sexual activity. He never dated and allowed no close male friendships. He later described his experience as “feeling like a damaged freak.” In his early teens, he began to abuse marijuana and alcohol.

Twice in his first week in the program, George had panic attacks that he blamed on fears of being trapped. He had nightmares almost every night and had rushes of feeling overwhelmed and ashamed. He appeared frightened and unable to bond with other male clients in the group. He became visibly anxious when asked, in individual appointments, about his sexual and interpersonal history.

In clinical supervision, the counselor described George's symptoms and problems on the unit, expressing concern that George might have a trauma-related disorder. The counselor's supervisor suggested screening George for trauma symptoms, and when the counselor did so, George began to allude to a history of sexual abuse. Subsequent mental health consultation confirmed a posttraumatic stress disorder (PTSD) diagnosis, and integrated treatment of PTSD and substance abuse was undertaken. Efforts were made to ensure that George's treatment did not unintentionally evoke his childhood sexual trauma. He was encouraged to speak with his counselor if his anxiety became intolerable and was given a private bedroom. Without offering details, he described to his primary treatment group that terrible things occurred in his childhood that made it hard to bond with others; he felt great relief in sharing part of his secret with others. Plans were made for George to continue individual treatment for PTSD and relapse prevention after successfully concluding inpatient treatment.

TIP 36 (CSAT 2000b) provides information on treating male and female survivors of child abuse and neglect in substance abuse treatment settings. Some basic guidelines are presented in the following text box.

## Family Issues

Men fill a number of different relationship roles. They may be employees or employers, and they may be involved with different systems (e.g., the criminal justice system)—both topics are discussed in Chapter 4—but most men have been or currently are members of families (either families of origin or those they have themselves created). Families can affect men's substance abuse in different ways, but they also can play a powerful role in motivating men to enter and maintain recovery.

Advice to Behavioral Health Clinicians: Addressing Childhood Sexual Trauma in Men

- Screen all male clients in substance abuse treatment for childhood sexual trauma.
- If screening reveals the possibility of childhood sexual trauma, have the client assessed by a clinician competent to diagnose and recommend treatment approaches for trauma.
- In treatment, focus on how the trauma affects the client today, not on the details of the trauma.
- Most clients prefer to work on the effects of their childhood trauma in individual, not group, sessions.
- Childhood sexual trauma may be part of a larger process of abuse and disrespect of the individual in childhood and into adulthood. Do not presume childhood sexual abuse to be an isolated incident.

### Parenting Responsibilities

Parenting can be a stressful activity for both men and women. Some fathers who abuse substances may believe their substance use actually helps them cope with stress associated with parenting, enhancing their ability to function as fathers. However, substance use is likely to increase child abuse and neglect and create a much more chaotic environment for children in the home (Ammerman et al. 1999; Reid et al. 1999). Paternal substance abuse has also been associated with negative outcomes for children, including children's own abuse of substances later in life (McMahon et al. 2005; Schuckit and Smith 2001); antisocial traits and higher rates of depression, anxiety, and mania (Finn et al. 1997); lower intelligence quotient (IQ) and school achievement scores (Moss et al. 1995b); and increased aggression (Moss et al. 1995a).

Father–child relationships within families affected by paternal substance abuse are not categorically problematic (Eiden et al. 2002), and there is some evidence that, even in the midst of chronic substance abuse, positive father–child relationships may still help promote positive child development (Brook et al. 2002a, b). Still, it is best that fathers contribute to the well-being of children when they are in a position to maintain close, responsive relationships with them, to provide emotional support and practical assistance to their children's mothers, and to contribute economically to the family's welfare, all of which are extremely difficult to do when abusing substances.

The importance of child custody for women and the value of programs that treat women with their children have been recognized for some time (CSAT 2004b), but clinicians and researchers still tend to minimize the roles played in the lives of their children by men who abuse substances (McMahon and Rounsaville 2002). Losing custody of their children can affect men's substance use; some men enter treatment due to their concern for their children (McMahon and Rounsaville 2002), and men who have children are more likely to complete treatment (Rabinowitz and Marjefsky 1998). Conversely, lack of contact with one's children is correlated with increased substance misuse among men (Grill et al. 2001).

Although empirical data on how parenting responsibilities affect the treatment seeking and retention of men are not readily available, studies suggest that family can play an important role in motivating a man to enter treatment. For example, Steinberg and colleagues (1997) found that 53.3 percent of their sample (105 men in a couples-based outpatient program for alcohol abuse) said they were motivated by their spouse or family to enter treatment. In analyzing data from the Drug Abuse Treatment Outcome Study, Grella and Joshi (1999) found that opposition to substance use and support for treatment from family members had an effect on men's entry into treatment that it did not have on women's entry. The authors also reported that despite not being as concerned with child custody issues as women, a significant number of men reported concern that entering treatment might affect custody of their children (15.7 of men compared with 30.5 percent of women) and that they might lose custody of their children because of their substance abuse (4.2 percent of men versus 16.9 percent of women).

The consensus panel believes that fatherhood and the desire to be a good father can serve to motivate a man to enter and remain in treatment as well as potentially hinder treatment entry. For example, concerns about working to provide financial support for children may prevent some men from seeking treatment in a timely manner, particularly if treatment requires absence from work. Similarly, internal or external pressure to return to work as soon as possible so that they can provide for their children may cause some men to leave treatment prematurely. Some fathers, particularly single custodial fathers, may avoid seeking treatment or leave treatment if they believe it could interfere with their ability to effectively parent their children. Also, men living with their children may be less likely to commit themselves to an extended period of inpatient, residential, or maintenance treatment. Men involved in family court proceedings might believe involvement in treatment could be used against them in hearings concerning child custody or visitation rights. For these reasons, among others, it is important for fathers to have some contact with their children during treatment, even if only through supervised visitation. Sensitivity to a father's visitation schedule helps him maintain contact with his children and ensures that custody exchanges proceed smoothly and both mother and father cooperate with the terms of the agreement.

#### Counseling fathers in substance abuse treatment

When entering treatment, men sometimes discover that they lack basic parenting skills—a problem they did not recognize when they were using. Substance abuse programs that treat male clients should consider adding a component that teaches parenting skills, as many men with children will express an interest in such an option if offered. Although formal evaluation data are scarce regarding parenting programs for men in treatment, criminal justice system providers believe they are helpful for both the men and their children; men are interested in such programs and view them favorably (Jeffries et al. 2001).

Given the complex, multidimensional nature of their problems, fathers who abuse substances may need a great deal of support and assistance from their counselors to be able to provide for and have close, healthy relationships with their children. Unfortunately, formal resources for clinicians interested in helping men become more effective parents are somewhat limited. There are generic parenting interventions, such as Focus on Families (Catalano et al. 2002) developed for use with both men and women with substance use disorders, as well as gender-specific approaches to parenting for mothers with substance use disorders that may be adapted to address the specific needs of men with substance dependence (e.g., see Luthar and Suchman 1999, 2000).

Advice to Behavioral Health Clinicians: Parenting Issues

Programs specifically designed to teach men parenting skills are almost universally absent in substance abuse treatment settings. Parental interventions for men with substance use disorders must systematically address the motivational, cognitive, behavioral, and interpersonal aspects of parenting from the perspective of men:

- Why men should work to become better parents.
- The benefits clients can receive by becoming better parents.
- Family-of-origin issues that may interfere with effective fathering.
- Legal barriers to greater involvement with children.
- Problem-solving with mothers who typically control access to children.
- Building better communication skills with children.
- Developing specific parenting skills appropriate for use with children of a specific age.
- Relating to children who are grown.

Cogent issues that can emerge for fathers with substance use disorders include:

- Excessive guilt about being an ineffective parent.
- Family secrets about substance use and HIV/AIDS status.
- Relating to children when both parents are addicted.
- Lack of role models for effective parenting.

Although educating fathers about parenting is important, the consensus panel recommends that behavioral health clinicians move beyond education and develop a more comprehensive parenting intervention that acknowledges the complex nature of parent–child relationships and the special needs of fathers. Because the parenting problems of men with substance use disorders range broadly from decisions to voluntarily terminate parental rights to new responsibilities to care for children as single custodial fathers, flexible treatment approaches are necessary. In their work with fathers enrolled in methadone maintenance, McMahon and Giannini (2002) found that parental interventions for men with substance use disorders must systematically address the motivational, cognitive, behavioral, and interpersonal aspects of parenting from the perspective of men, including:

- Why men should work to become better parents.
- The benefits clients can receive by becoming better parents.
- Family-of-origin issues that may interfere with effective fathering.
- Legal barriers to greater involvement with children.
- Problem-solving with mothers who typically control access to children.
- Building better communication skills with children.
- Developing parenting skills appropriate for use with children of a specific age.
- Relating to children who are grown.

When working with fathers who have substance use disorders, behavioral health clinicians should be particularly aware of the possibility of treating men who have excessive guilt about being an ineffective parent, have family secrets about substance use and HIV/AIDS status, have children with a woman who abuses substances, and/or who are overwhelmed with sole custody.

Family Issues: Helpful Resources for Behavioral Health Service Providers

Programs specifically designed to teach men parenting skills are almost universally absent in substance abuse treatment settings. Parental interventions for men with substance use disorders must systematically address the motivational, cognitive, behavioral, and interpersonal aspects of parenting from the perspective of men:

- SAMHSA's toolkit, Supportive Education for Children of Addicted Parents (http://store.samhsa.gov/), provides materials to help substance abuse programs initiate educational support programs for children of clients in substance abuse treatment. The programs teach youth skills, such as problem-solving, coping, social competence, autonomy, and sense of purpose. Although the material is oriented toward Native American communities, it can easily be adapted for use with non-Native groups.
- The Center for Substance Abuse Prevention's guide, Helping Children and Adolescents in Families Affected by Substance Use (http://www.nacoa.net/pdfs/guide%20for%20health.pdf), presents information and tools to help healthcare practitioners ask questions and intervene with patients and families experiencing substance-related difficulties.
- SAMHSA's National Center on Substance Abuse and Child Welfare has produced a toolkit (http://www.ncsacw.samhsa.gov/training/toolkit/) that provides child welfare workers with learning opportunities and baseline knowledge relating to substance use and mental disorders and interventions while motivating and facilitating cross-systems work. The toolkit also addresses cultural awareness and offers ways to facilitate cultural competence in child welfare practice.

Although both fathers and children stand to benefit from improvement in father–child relationships, clinicians may encounter situations in which it is not practical, feasible, or safe to promote a client's greater involvement in his child's life. Geographic distance, children's refusal to see their fathers, obstructive mothers, and angry members of the extended family may complicate men's efforts to improve their relationships with their children. Ongoing substance use, past or present domestic violence, allegations of child abuse, and ongoing involvement in criminal activity may raise ethical questions about promoting involvement that may prove harmful to children or partners, particularly as ongoing research begins to better define those circumstances (Jaffe et al. 2003). Similarly, when men have systematically abused or neglected children for a long period of time, clinicians may need to help them negotiate difficult decisions about petitions for extended placement of children, voluntary termination of parental rights, and/or adoption by others interested in functioning as parents.

### Reproductive Responsibility

Most interventions focusing on male sexuality emphasize the prevention of sexually transmitted diseases—if discussed at all, issues of unwanted paternity seem to be of secondary concern. However, what little information exists about patterns of family formation among men with substance use disorders suggests that, as a group, they may have more children with more partners than do other men, have their first child earlier in the lifecycle, and father the majority of their children before the onset of their substance use disorders (McMahon 2003; McMahon et al. 2005). Substance abuse treatment programs are an ideal setting in which to raise and discuss issues about male sexuality, unwanted paternity, and reproductive responsibility.

### Legal Issues Affecting Families

#### Child support

Fathers with substance abuse problems are twice as likely to fail to pay child support as those without such problems (Garfinkel et al. 1998). The Child Support Enforcement Program links Federal, State, and local authorities to ensure that orders for child support are followed. A father's wages may be garnished to pay for back child support, and drivers' and professional licenses can be revoked, passports denied, and financial institution deposits seized (ACF 2002). All of this may add to the stress of a father who is in substance abuse treatment and unable to meet child support payments.

#### Family court involvement

Men seeking substance abuse treatment may need support and assistance in navigating the child welfare and family court systems. As stereotypes involving substance abuse collide with traditional ideas about family life, men involved in family court proceedings may experience bias that labels them as entirely negative influences to be excluded from the family (McMahon and Giannini 2003). Stereotypes of men who abuse substances may reinforce traditional ideas about gender and family such that these men, more so than others, are quickly but inappropriately dismissed as indifferent, uninvolved, irresponsible, and irrelevant (McMahon and Giannini 2003; Parke and Brott 1999).

When fathers with substance use disorders are involved in family court proceedings, the courts use clinical evaluations to inform their decisions. As McMahon and Giannini (2003) note, comprehensive, integrated evaluations of fathers who abuse substances should:

- Characterize the nature of the substance use.
- Document the presence of other behavioral health problems.
- Highlight capacity for effective parenting.
- Document compromise of parenting.
- Characterize treatment needs.
- Offer comment about the adequacy of whatever treatment might be occurring.

Professionals working with fathers who have substance use disorders should support, as much as possible, the self-defined goals of their clients and should, with proper authorization, give family courts information about ongoing treatment to use in making decisions.

Clinicians providing ongoing substance abuse treatment to fathers may have to educate court personnel about their ethical obligation to advance the interests of their clients and their need to remain, as much as possible, a neutral party in family court proceedings. Treating clinicians should not offer opinions about visitation, custody, termination of parental rights, or similar matters if they are to continue their clinical intervention with a given client, regardless of legal outcome.

### Support From Partners, Family, and Friends

The personal relationships of men who abuse substances can either help bring about change in their lives or contribute to the problem. Associating with friends with whom one used substances is a common trigger for relapse. Vaillant and Hiller-Sturmhofel found that warm and cohesive environments and close relationships were more common among men who did not develop alcohol use disorders than among those who did (1996). Various studies also indicate that men who have wives and/or children tend to use substances less frequently and in smaller amounts than those without such ties (Blazer and Wu 2009b; HHS, SAMHSA, Office of Applied 2008a, 2009b; Kuntsche et al. 2009). Having friends who drink heavily and/or use drugs is strongly associated with such behavior for men (Weisner et al. 2003), and not having such friends is associated with better recovery outcomes (Christakis and Fowler 2008; Flynn et al. 2003; Laudet et al. 2006). Clinicians who understand the power of family and other personal relationships in men's lives can actively address these issues through couples and/or family treatment or through building other social supports (such as mutual-help group support, discussed in Chapter 5) to help men struggling with substance use minimize their likelihood of resuming substance-related behavior.

Having a partner or family member who supports treatment for substance abuse is likely to improve its outcome. When men are not in relationships (or have no children), they are less likely to complete treatment (Rabinowitz and Marjefsky 1998). Counselors can help clients improve marital and family relationships through psychoeducational programs, relationally oriented group counseling, and couples counseling that emphasizes supporting treatment and recovery efforts, managing interpersonal struggles and crises, and building relational strengths, such as marital communication and parenting skills.

Although partner and family support is certainly important, behavioral health clinicians should not overlook the influence a man's friends have on treatment outcomes. Including men's friends in some aspect of the treatment process can be of great value if they are supportive and not abusing substances themselves. Unfortunately, deteriorating or absent friendships can be a barrier to successful substance abuse treatment. Although men 55 to 65 years of age who abuse alcohol were found to experience more support from their spouses, they received less support from their “children, extended family members, and friends” (Brennan et al. 1993, p. 781). These men also reported more chronic stress in their lives, in part because of the state of their relationships with friends (Brennan et al. 1993).

## Spirituality and Religion

Most clients in substance abuse treatment usually have some religious and/or spiritual beliefs, based on research in medical settings (Koenig 2001b) and among the general population (Public Broadcasting Service 2002; Robinson 2003). Spiritual and religious activity should generally be encouraged; research has repeatedly confirmed that people who participate in spiritual/religious activities are less likely to abuse substances (Koenig 2001b). Also, religious practices and beliefs (at least those from established religions) seem to affect physical health by improving coping, reducing emotional distress, improving attitude and mood, increasing social support, and reducing problem behaviors (Koenig 2001a).

Due to the influence of 12-Step groups like Alcoholics Anonymous, spiritual beliefs play an important role in many substance abuse treatment programs. Many clients find that spiritual and/or religious beliefs (the difference is defined in the text box below) play an important role in their recovery, so counselors should be prepared to discuss these beliefs with clients if they so choose.

Counselors in behavioral health settings can use a male client's religious or spiritual beliefs to motivate change and, sometimes, to counter the negative effects of certain cultural beliefs about masculinity and alcohol use. For example, a client who believes that not drinking will jeopardize his masculinity and status among his peers may be better able to reconcile his decision to maintain abstinence as a culturally appropriate one if it is supported by a priest or clergyman. Faith can also help recovering clients as they reenter their communities; support from a church, synagogue, mosque, or other faith-based institution can improve their chances of recovery and reduce the odds of relapse (CSAT 1999b).

Although substances (such as wine or peyote) may be used in some religious rituals, all major religions have made adaptations for individuals with substance use disorders, enabling them to participate in the religion without partaking of those substances.

Behavioral health services providers should become familiar with their clients' spiritual beliefs, practices, and experiences just as they learn about their occupations, families, habits, and mental health. (See Chapter 2 for information on assessing clients' spiritual/religious beliefs.) In a therapeutic relationship of mutual respect and tolerance, differences between counselor and client in spiritual beliefs need not become problematic. A clinician can serve as an orchestrator of resources when it comes to a client's religious or spiritual beliefs (Koenig 2001b). Just as the clinician or other appropriate staff person can help clients get the physical services they need (e.g., housing, medical care), they can also help clients meet their spiritual needs by arranging visits with spiritual advisors or clergy, as well as by providing access to religious services during treatment upon client request. Clinicians must be able to refer clients to spiritual advisors from many different faiths (reflecting the population with which the clinician works).

Defining the Difference Between Religion and Spirituality

It is useful to distinguish between spirituality and religion, as some men seeking treatment view themselves as spiritual but not necessarily religious. Religion is organized, with each religion having its own “theology, doctrine, creeds, catechisms, and liturgical practices, all of which are intended to enhance each member's spirituality” (Chappel 2003, p. 970). Spirituality, on the other hand, is a personal matter involving the individual's search for meaning, and it does not require an affiliation with any religion. People can have spiritual experiences or develop their own spirituality regardless of the presence or absence of any religious connection (Chappel 2003). In recovery from substance abuse, focusing on spirituality rather than religion can help some people accept the need for a higher power or a power greater than themselves (which could be other people, nature, a spiritual being, or a deity) when they might otherwise be resistant toward organized religion (Hazelden Foundation 2003).