# Appendix E Acknowledgments

Numerous people contributed to the development of this Treatment Improvement Protocol (TIP); see pages v-viii and Appendices C and D. Rose M. Urban, M.S.W., J.D., LCSW, LCAS, served as the Knowledge Application Program (KAP) Executive Project Co-Director. Sheldon Weinberg, Ph.D., served as the KAP Senior Researcher/Applied Psychologist. Other KAP personnel included Claudia Blackburn, Psy.D., Expert Content Director; Bruce Carruth, Ph.D., former Expert Content Director; Jessica L. Culotta, M.A., Managing Project Co-Director and former Managing Editor; Susan Kimner, former Managing Project Co-Director; Elizabeth Marsh Cupino, former Managing Project Co-Director; Raquel Witkin, M.S., former Deputy Project Manager; Jonathan Max Gilbert, Ph.D., Editor/Writer; Deborah Steinbach, M.A., former Editor/Writer; James M. Girsch, Ph.D., former Editor/Writer; Jason P. Merritt, former Editor/Writer; Virgie D. Paul, M.L.S., Librarian; Elizabeth Plevyak, former Associate Editor; Lee Ann Knapp, Quality Assurance Editor; Michelle Myers, former Quality Assurance Editor; Angela Fiastro, Junior Editor; and Ilana Boivie, Sonja Easley, and Joseph Killiany