# Appendix D Field Reviewers

- Gary L. Baker, LCSW
  Director, Social Services
  Office of Addictive Disorders
  Pines Treatment Center
  Shreveport, LA
- Mona R. Bomgaars
  Member
  Commission on Public Health
  American Academy of Family Physicians
  Honolulu, HI
- Patricia T. Bowman
  Probation Counselor
  Fairfax Alcohol Safety Action Program
  Fairfax, VA
- Frank Canizales, M.S.W.
  Management Analyst
  Alcohol Program
  Division of Clinical and Preventive Services
  Indian Health Service
  Rockville, MD
- Jerome F.X. Carroll, Ph.D.
  Consultant in Private Practice
  Chair
  Columbia University Drugs and Society Seminar
  Brooklyn, NY
- Redonna K. Chandler, Ph.D.
  Health Scientist Administrator
  Services Research Branch
  Division of Epidemiology, Services, and Prevention Research
  National Institute on Drug Abuse
  National Institutes of Health
  Bethesda, MD
- R. T. Codd, III
  Director/Owner
  Cognitive–Behavioral Therapy Center of Western North Carolina
  Certified Member of the Academy of Cognitive Therapy
  Asheville, NC
- Marc S. Condojani
  Clinical Training Coordinator
  Alcohol and Drug Abuse Division
  Colorado Department of Human Services
  Denver, CO
- Jerry P. Flanzer, D.S.W., LCSW, CAC
  Chief
  Services Research Branch
  National Institute on Drug Abuse
  National Institutes of Health
  Bethesda, MD
- Thomas L. Geraty, M.S.W., Ph.D., LICSW
  Jamaica Plain, MA
- Wendy K. Hausotter
  Project Manager
  Northwest Frontier Addiction Technology Transfer Center
  Salem, OR
- Heather Healy, LCSW-C, CCDC, CEAP
  Association of Flight Attendants
  Washington, DC
- Maya D. Hennessey
  Women's Specialist
  Supervisor, Quality Assurance, Technical Assistance and Training
  Office of Special Programs
  Division of Substance Abuse
  Illinois Department of Human Services and Substance Abuse
  Chicago, IL
- Michael W. Herring
  Licensed Clinical Social Worker
  Wayne Psychiatric Associates, PA.
  Goldsboro, NC
- Kenneth J. Hoffman, M.D., M.P.H.
  Medical Director
  Military Health System Population Health Programs
  TRICARE Management Activity
  Falls Church, VA
- Norman G. Hoffmann
  President
  Evince Clinical Assessments
  Clinical Associate Professor of Community Health
  Brown University
  Smithfield, RI
- David M. Kaplan, Ph.D.
  Associate Executive Director
  Professional Affairs
  American Counseling Association
  Alexandria, VA
- Michael Warren Kirby, Jr., M.A., Ph.D.
  Chief Executive Officer
  Arapahoe House, Inc.
  Thornton, CO
- Jan Ligon, Ph.D., LCSW
  Associate Professor
  School of Social Work
  Georgia State University
  Atlanta, GA
- Alan Lyme
  Program Manager
  Center for Men's Recovery
  Hanley–Hazelden Center
  West Palm Beach, FL
- Irmo Marini, Ph.D., CRC, CLCP, FVE
  Professor/Graduate Program Coordinator
  Rehabilitative Services Program
  College of Health Sciences and Human Services
  University of Texas–Pan American
  Edinburg, TX
- Thomas J. McMahon, Ph.D.
  Assistant Professor
  Yale University School of Medicine
  West Haven, CT
- Cece McNamara, Ph.D.
  Health Scientist Administrator
  Behavioral Treatment Development Branch
  Division of Treatment Research
  National Institute on Drug Abuse
  National Institutes of Health
  Bethesda, MD
- Karen H. Mooney
  Women's Treatment Coordinator
  Alcohol and Drug Abuse Division
  Colorado Department of Human Services
  Denver, CO
- Dennis Morrow
  Executive Director
  JANUS Youth Programs
  Portland, OR
- Robert L. Neri
  Vice President/Chief Clinical Officer
  WestCare Foundation, Inc.
  St. Petersburg, FL
- William (Bill) Francis Northey, Jr., Ph.D.
  Research Specialist
  American Association for Marriage and Family Therapy
  Alexandria, VA
- Charles Parker
  Project Specialist
  James R. Thompson Center
  Division of Alcoholism and Substance Abuse
  Illinois Department of Human Services
  Chicago, IL
- Thomas A. Peltz, M.Ed.
  Therapist/Licensed Mental Health Counselor
  Certified Addiction Specialist
  Private Practice
  Beverly Farms, MD
- Melissa V. Rael
  Senior Program Management Officer
  Co-Occurring and Homeless Branch
  Division of State and Community Assistance
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Pat Regan
  Social Work Supervisor
  Louisiana Department of Health and Hospitals
  Monroe, LA
- John A. Rich, M.D., M.P.H.
  Medical Director/Associate Professor
  Boston Public Health Commission
  Boston University School of Medicine
  Boston, MA
- Julie A. Sabol
  Web Marketing Specialist
  Customer Loyalty Practice
  ORC Macro
  Calverton, MD
- Michael D. Shankle, M.P.H.
  Research Specialist
  Pennsylvania Prevention Project
  Graduate School of Public Health
  Department of Infectious Diseases and Microbiology
  University of Pittsburgh
  Pittsburgh, PA
- Mark R. Shields
  Program Specialist II
  Division of Alcohol and Drug Abuse
  Missouri Department of Mental Health
  Jefferson City, MO
- Mickey J. W. Smith, M.S.W.
  Senior Policy Associate
  Behavioral Health Program
  Policy and Practice Unit
  Division of Professional Development and Advocacy
  National Association of Social Workers
  Washington, DC
- Richard T. Suchinsky, M.D.
  Associate Chief for Addictive Disorders and Psychiatric Rehabilitation
  Mental Health and Behavioral Sciences Services
  Department of Veterans Affairs
  Washington, DC
- Melvin H. Wilson, M.B.A., LCSW-C
  High Intensity Drug Trafficking Area Coordinator
  Maryland Division of Parole and Probation
  Baltimore, MD