# Appendix C Resource Panel

- John C. Bailey
  Special Expert
  Office of Policy, Planning, and Budget
  Office of the Administrator
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Frank Canizales, M.S.W.
  Management Analyst
  Alcohol Program
  Division of Clinical and Preventive Services
  Indian Health Service
  Rockville, MD
- Redonna K. Chandler, Ph.D.
  Health Scientist Administrator
  Services Research Branch
  Division of Epidemiology, Services, and Prevention Research
  National Institute on Drug Abuse
  National Institutes of Health
  Bethesda, MD
- Christine Cichetti
  Drug Policy Advisor
  U.S. Department of Health and Human Services
  Washington, DC
- H. Westley Clark, M.D., J.D., M.P.H., CAS, FASAM
  Director
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Edwin M. Craft, Dr.P.H.
  Program Analyst
  Practice Improvement Branch
  Division of Services Improvement
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Christina Currier
  Public Health Analyst
  Practice Improvement Branch
  Division of Services Improvement
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Jerry P. Flanzer, D.S.W., LCSW, CAC
  Chief
  Services Research Branch
  National Institute on Drug Abuse
  National Institutes of Health
  Bethesda, MD
- Kirk E. James, M.D.
  Special Expert
  Systems Improvement Branch
  Division of Services Improvement
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Andrea Kopstein, Ph.D., M.P.H.
  Branch Chief
  Practice Improvement Branch
  Division of Services Improvement
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Cece McNamara, Ph.D.
  Health Scientist Administrator
  Behavioral Treatment Development Branch
  Division of Treatment Research
  National Institute on Drug Abuse
  National Institutes of Health
  Bethesda, MD
- Julie A. Sabol
  Web Marketing Specialist
  Customer Loyalty Practice
  ORC Macro
  Calverton, MD
- Michael D. Shankle, M.P.H.
  Research Specialist
  Pennsylvania Prevention Project
  Graduate School of Public Health
  Department of Infectious Diseases and Microbiology
  University of Pittsburgh
  Pittsburgh, PA
- Richard T. Suchinsky, M.D.
  Associate Chief for Addictive Disorders and Psychiatric Rehabilitation
  Mental Health and Behavioral Sciences Services
  Department of Veterans Affairs
  Washington, DC
- Karl D. White, Ed.D.
  Public Health Analyst
  Practice Improvement Branch
  Division of Services Improvement
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD