# Appendix A Bibliography

Abe-Kim J, Takeuchi DT, Hong S, Zane N, Sue S, Spencer MS, Appel H, Nicdao E, Alegria M. (2007). Use of mental health-related services among immigrant and U.S.-born Asian Americans: Results From the National Latino and Asian American Study. American Journal of Public Health.
Abueg FR, Fairbank JA. (1992). Behavioral treatment of posttraumatic stress disorder and co-occurring substance abuse. Saigh PA, editor. Posttraumatic Stress Disorder: A Behavioral Approach to Assessment and Treatment.
Adams WL, Cox NS. (1995). Epidemiology of problem drinking among elderly people. International Journal of the Addictions.
Addis ME, Mahalik JR. (2003). Men, masculinity, and the contexts of help seeking. American Psychologist.
Administration for Children and Families. (2002). Child Support Enforcement Program Fact Sheet.
Administration for Children and Families. (2004). Child Maltreatment 2002: Reports From the States to the National Center on Child Abuse and Neglect.
Aguirre-Molina M, Molina CW, Zambrana RE. (2001). Health Issues in the Latino Community.
Albanese MJ, Clodfelter RC, Pardo TB, Ghaemi SN. (2006). Underdiagnosis of bipolar disorder in men with substance use disorder. Journal of Psychiatric Practice.
Alcoholics Anonymous World Services. (1984). The AA Member—Medications and Other Drugs: A Report From a Group of Physicians in AA.
Alcoholics Anonymous World Services. (2001). Alcoholics Anonymous: The Story of How Many Thousands of Men and Women Have Recovered From Alcoholism.
Alcoholics Anonymous World Services. (2008). Alcoholics Anonymous 2007 Membership Survey.
Alegria M, Chatterji P, Wells K, Cao Z, Chen CN, Takeuchi D, Jackson J, Meng XL. (2008). Disparity in depression treatment among racial and ethnic minority populations in the United States. Psychiatric Services.
Alexander PC, Morris E. (2008). Stages of change in batterers and their response to treatment. Violence and Victims.
(2003). Allen JP, Columbus M, editors. Assessing Alcohol Problems: A Guide for Clinicians and Researchers.
Alvarez LR, Ruiz P. (2001). Substance abuse in the Mexican American population. Straussner SLA, editor. Ethnocultural Factors in Substance Abuse Treatment.
Amaro H, Arévalo S, Gonzalez G, Szapocznik J, Iguchi MY. (2006). Needs and scientific opportunities for research on substance abuse treatment among Hispanic adults. Drug and Alcohol Dependence.
American Lung Association. (2006). Trends in Tobacco Use.
American Psychiatric Association. (2000). Diagnostic and Statistical Manual of Mental Disorders.
American Society of Addiction Medicine. (2001). Patient Placement Criteria for the Treatment of Substance-Related Disorders: ASAM PPC-2R.
Ammerman RT, Kolko DJ, Kirisci L, Blackson TC, Dawes MA. (1999). Child abuse potential in parents with histories of substance use disorder. Child Abuse and Neglect.
Amodeo M, Peou S, Grigg-Saito D, Berke H, Pin-Riebe S, Jones LK. (2004). Providing culturally specific substance abuse services in refugee and immigrant communities: Lessons from a Cambodian treatment and demonstration project. Journal of Social Work Practice in the Addictions.
Andersson T, Mahoney JL, Wennberg P, Kuhlhorn E, Magnusson D. (1999). The co-occurrence of alcohol problems and criminality in the transition from adolescence to young adulthood: A prospective longitudinal study on young men. Studies on Crime and Crime Prevention.
Andrews B, Qian M, Valentine JD. (2002). Predicting depressive symptoms with a new measure of shame: The Experience of Shame Scale. British Journal of Clinical Psychology.
Angrist BM. (1987). Clinical effects of central nervous system stimulants: A selective update. Engel J, Oreland L, editors. Brain Reward Systems and Abuse.
Antai-Otong D. (2003). Suicide: Life span considerations. Nursing Clinics of North America.
Araujo NP, Monteiro MG. (1995). Family history of alcoholism and psychiatric co-morbidity in Brazilian male alcoholics and controls. Addiction.
Archer J. (2002). Sex differences in physically aggressive acts between heterosexual partners: A meta-analytic review. Aggression and Violent Behavior.
Arfken CL, Kubiak SP, Koch AL. (2007). Health issues in the Arab American community. Arab Americans in publicly financed substance abuse treatment. Ethnicity and Disease.
Arndt S, Black DW, Schmucker A, Zwick J. (2004). Association among outcomes in a naturalistic statewide assessment of substance user treatment. Substance Use & Misuse.
Arnold LM. (2003). Gender differences in bipolar disorder. Psychiatric Clinics of North America.
Arsenault-Lapierre G, Kim C, Turecki G. (2004). Psychiatric diagnoses in 3275 suicides: A meta-analysis. BMC Psychiatry.
Atkinson RM, Tolson RL, Turner JA. (1993). Factors affecting outpatient treatment compliance of older male problem drinkers. Journal of Studies on Alcohol.
Attridge M, Amaral T, Bjornson T, Goplerud E, Herlihy P, McPherson T, Paul R, Routledge S, Sharar D, Stephenson D, Teems L. (2009). History and growth of the EAP field. EASNA Research Notes.
Awalt RM, Reilly PM, Shopshire MS. (1997). The angry patient: An intervention for managing anger in substance abuse treatment. Journal of Psychoactive Drugs.
(1999). Awalt RM, Shopshire MS, Reilly PM, Hall SM, Harris LS, editors. Anger Problems in Substance Abuse Treatment.
Ayuso-Gutierrez JL, del Rio Vega JM. (1997). Factors influencing relapse in the long-term course of schizophrenia. Schizophrenia Research.
Bacaner N, Kinney TA, Biros M, Bochert S, Casuto N. (2002). The relationship among depressive and alcoholic symptoms and aggressive behavior in adult male emergency department patients. Academic Emergency Medicine.
Baetz M, Griffin R, Bowen R, Koenig HG, Marcoux E. (2004). The association between spiritual and religious involvement and depressive symptoms in a Canadian population. Journal of Nervous and Mental Disease.
Bailey L, Maxwell S, Brandabur MM. (1997). Substance abuse as a risk factor for tardive dyskinesia: A retrospective analysis of 1,027 patients. Psychopharmacology Bulletin.
Barbara AM, Chaim G. (2004). Asking about sexual orientation during assessment for drug and alcohol concerns: A pilot study. Journal of Social Work Practice in the Addictions.
Barnes JS, Bennett CE. (2001). The Asian Population: 2000.
Barret RL. (1996). Gay fathers in groups. Andronico MP, editor. Men in Groups: Insights, Interventions, and Psychoeducational Work.
Bartholomew K, Regan KV, Oram D, White MA. (2008). Correlates of partner abuse in male same-sex relationships. Violence and Victims.
Bartholomew NG, Hiller ML, Knight K, Nucatola DC, Simpson DD. (2000). Effectiveness of communication and relationship skills training for men in substance abuse treatment. Journal of Substance Abuse Treatment.
Bartholomew NG, Simpson DD. (2002). Time Out!for Men: A Communications Skills and Sexuality Workshop for Men.
Bebbington P, Dunn G, Jenkins R, Lewis G, Brugha T, Farrell M, Meltzer H. (2003). The influence of age and sex on the prevalence of depressive conditions: Report from the National Survey of Psychiatric Morbidity. International Review of Psychiatry.
(2004). Begun A, editor. Module 10D: Alcohol Use Disorders in Homeless Populations.
Begun AL, Brondino MJ, Bolt D, Weinstein B, Strodthoff T, Shelley G. (2008). The Revised Safe at Home instrument for assessing readiness to change intimate partner violence. Violence and Victims.
Bekker MH, van Mens-Verhulst J. (2007). Anxiety disorders: Sex differences in prevalence, degree, and background, but gender-neutral treatment. Gender Medicine.
Bell NJ, Kanitkar K, Kerksiek KA, Watson W, Das A, Kostina-Ritchey E, Russell MH, Harris K. (2009). “It has made college possible for me”: Feedback on the impact of a university-based center for students in recovery. Journal of American College Health.
Bennett LW. (1995). Substance abuse and the domestic assault of women. Social Work.
Bennett L, Lawson M. (1994). Barriers to cooperation between domestic violence and substance-abuse programs. Families in Society.
Berger JM, Levant R, McMillan KK, Kelleher W, Sellers A. (2005). Impact of gender role conflict, traditional masculinity ideology, alexithymia, and age on men's attitudes toward psychological help seeking. Psychology of Men & Masculinity.
Bergman B, Brismar B. (1994). Characteristics of imprisoned wife-beaters. Forensic Science International.
Bergman SJ. (1995). Men's psychological development: A relational perspective. Levant RF, Pollack WS, editors. A New Psychology of Men.
Bernstein DP, Fink L. (1998). Childhood Trauma Questionnaire: A Retrospective Self-Report Questionnaire and Manual.
Bernstein DP, Fink L, Handelsman L, Foote J, Lovejoy M, Wenzel K, Sapareto E, Ruggiero J. (1994). Initial reliability and validity of a new retrospective measure of child abuse and neglect. American Journal of Psychiatry.
Bernstein DP, Stein JA, Newcomb MD, Walker E, Pogge D, Ahluvalia T, et al. (2003). Development and validation of a brief screening version of the Childhood Trauma Questionnaire. Child Abuse & Neglect.
Bertakis KD. (2009). The influence of gender on the doctor-patient interaction. Patient Education and Counseling.
Bertakis KD, Franks P, Azari R. (2003). Effects of physician gender on patient satisfaction. Journal of the American Medical Women's Association.
Betcher RW, Pollack WS. (1993). In a Time of Fallen Heroes: The Re-Creation of Masculinity.
Betz NE, Fitzgerald LF. (1993). Individuality and diversity: Theory and research in counseling psychology. Annual Review of Psychology.
Bhasin S, Gabelnick HL, Spieler JM, Swerdloff RS, Wang C, Kelly C. (1996). Pharmacology, Biology, and Clinical Applications of Androgens: Current Status and Future Prospects. Proceedings of the Second International Androgen Workshop.
Biddle L, Gunnell D, Sharp D, Donovan JL. (2004). Factors influencing help-seeking in mentally distressed young adults: A cross-sectional survey. British Journal of General Practice.
Bielawski DM, Zaher FM, Svinarich DM, Abel EL. (2002). Paternal alcohol exposure affects sperm cytosine methlytransferase messenger RNA levels. Alcoholism: Clinical and Experimental Research.
Black DW, Carney CP, Forman-Hoffman VL, Letuchy E, Peloso PM, Woolson RF, Doebbeling BN. (2004). Depression in veterans of the first Gulf War and comparable military controls. Annals of Clinical Psychiatry.
Black MM, Krishnakumar A. (1998). Children in low-income, urban settings: Interventions to promote mental health and well-being. American Psychologist.
Blake WM, Darling CA. (1994). The dilemmas of the African American male. Journal of Black Studies.
Blazer DG, Wu LT. (2009). The epidemiology of at-risk and binge drinking among middle-aged and elderly community adults: National Survey on Drug Use and Health. American Journal of Psychiatry.
Blazer DG, Wu LT. (2009). Nonprescription use of pain relievers by middle-aged and elderly community-living adults: National Survey on Drug Use and Health. Journal of the American Geriatric Society.
Blazina C, Watkins CE. (1996). Masculine gender role conflict: Effects on college men's psychological well-being, chemical substance usage, and attitudes towards help-seeking. Journal of Counseling Psychology.
Blumenthal DJ. (1988). Suicide: A guide to risk factor, assessment, and treatment of suicidal patients. Medical Clinics of North America.
Bock R. (1993). Understanding Klinefelter Syndrome: A Guide for XXY Males and Their Families.
Boer DP, Wilson RJ, Gauthier CM, Hart SD. (1997). Assessing risk for sexual violence: Guidelines for clinical practice. Webster CD, Jackson MA, editors. Impulsivity, Theory, Assessment and Treatment.
Booth A, Johnson DR, Granger DA. (1999). Testosterone and men's depression: The role of social behavior. Journal of Health and Social Behavior.
Bourgois P. (2003). In Search of Respect: Selling Crack in El Barrio.
Brady KT, Randall CL. (1999). Gender differences in substance use disorders. Psychiatric Clinics of North America.
Brannon L. (2005). Gender: Psychological Perspectives.
Brannon R. (1976). The male sex role: Our culture's blueprint for manhood. What it's done for us lately. David DS, Brannon R, editors. The Forty-Nine Percent Majority: The Male Sex Role.
Brannon R, Juni S. (1984). A scale for measuring attitudes about masculinity. Psychological Documents.
Braun-Harvey DK. (1997). Sexual dependence among recovering substance-abusing men. Straussner SLA, Zelvin E, editors. Gender and Addictions: Men and Women in Treatment.
Brennan PL, Moos RH, Kim JY. (1993). Gender differences in the individual characteristics and life contexts of late-middle-aged and older problem drinkers. Addiction.
Breslau N. (2002). Gender differences in trauma and posttraumatic stress disorder. Journal of Gender Specific Medicine.
Breslau N, Kessler RC, Chilcoat HD, Schultz LR, Davis GC, Andreski P. (1998). Trauma and posttraumatic stress disorder in the community: The 1996 Detroit Area Survey of Trauma. Archives of General Psychiatry.
Bride BE. (2001). Single-gender treatment of substance abuse: Effect on treatment retention and completion. Social Work Research.
Brook DW, Brook JS, Richter L, Whiteman M, Arencibia-Mireles O, Masci JR. (2002). Marijuana use among the adolescent children of high-risk drug-abusing fathers. American Journal on Addictions.
Brook DW, Brook JS, Whiteman M, Arencibia-Mireles O, Pressman MA, Rubenstone E. (2002). Coping in adolescent children of HIV-positive and HIV-negative substance-abusing fathers. Journal of Genetic Psychology.
Brook DW, Brook JS, Zhang C, Cohen P, Whiteman M. (2002). Drug use and the risk of major depressive disorder, alcohol dependence, and substance use disorders. Archives of General Psychiatry.
Brooks GR. (1995). Rituals and celebrations in men's lives. SPSMM Bulletin.
Brooks GR. (1996). Treatment for therapy-resistant men. Andronico MP, editor. Men in Groups: Insights, Interventions, and Psychoeducational Work.
Brooks GR. (1998). A New Psychotherapy for Traditional Men.
Brooks GR. (2001). Masculinity and men's mental health. Journal of American College Health.
(2001). Brooks GR, Good GE, editors. The New Handbook of Psychotherapy and Counseling With Men: A Comprehensive Guide to Settings, Problems, and Treatment Approaches.
Brooks GR, Silverstein LB. (1995). Understanding the dark side of masculinity. Levant RF, Pollack WS, editors. A New Psychology of Men.
Brower KJ, Carey TL. (2003). Racially related health disparities and alcoholism treatment outcomes. Alcoholism, Clinical and Experimental Research.
Brown BS, O'Grady K, Battjes RJ, Farrell EV. (2004). Factors associated with treatment outcomes in an aftercare population. American Journal of Addiction.
Brown K, Bradley LJ. (2002). Reducing the stigma of mental illness. Journal of Mental Health Counseling.
Brown LS, Alterman AI, Rutherford MJ, Cacciola JS, Zaballero AR. (1993). Addiction Severity Index scores of four racial/ethnic and gender groups of methadone maintenance patients. Journal of Substance Abuse.
Brown RA. (2010). Crystal Methamphetamine Use Among American Indian and White Youth in Appalachia: Social Context, Masculinity, and Desistance.
Brown TG, Caplan T, Werk A, Seraganian P. (1999). The comparability of male violent substance abusers in violence or substance abuse treatment. Journal of Family Violence.
Brunswick AF, Messeri PA. (1999). Life stage, substance use and health decline in a community cohort of urban African Americans. Journal of Addictive Diseases.
Burda PC, Tushup RJ, Hackman PS. (1992). Masculinity and social support in alcoholic men. Journal of Men's Studies.
Bureau of Justice Statistics. (2005). Drugs and Crime Facts. Drug Use and Crime.
Burke LK, Follingstad DR. (1999). Violence in lesbian and gay relationships: Theory, prevalence, and correlational factors. Clinical Psychology Review.
Burke M. (1999). Real men don't drink. New Scientist.
Burling TA, Seidner AL, Robbins-Sisco D, Krinsky A, Hanser SB. (1992). Batter up! Relapse prevention for homeless veteran substance abusers via softball team participation. Journal of Substance Abuse.
Burns PC, Wilde GJS. (1995). Risk taking in male taxi drivers: Relationships among personality, observational data and driver records. Personality and Individual Differences.
Burt MR, Aron LY, Douglas T, Valente J, Lee E, Iwen B. (1999). Homelessness: Programs and the People They Serve. Findings of the National Survey of Homeless Assistance Providers and Clients.
Buss TF, Abdu R, Walker JR. (1995). Alcohol, drugs, and urban violence in a small city trauma center. Journal of Substance Abuse Treatment.
Button TM, Rhee SH, Hewitt JK, Young SE, Corley RP, Stallings MC. (2007). The role of conduct disorder in explaining the comorbidity between alcohol and illicit drug dependence in adolescence. Drug and Alcohol Dependence.
Caetano R. (1988). Alcohol use among Hispanic groups in the United States. American Journal of Drug and Alcohol Abuse.
Caetano R. (1988). Alcohol use among Mexican Americans and in the U.S. population. Gilbert MJ, editor. Alcohol Consumption Among Mexicans and Mexican Americans: A Binational Perspective.
Caetano R, Schafer J, Cunradi CB. (2001). Alcohol-related intimate partner violence among White, Black, and Hispanic couples in the United States. Alcohol Research and Health.
Calamari JE, Cox WM, Roth JD. (1996). Group treatments for men with alcohol problems. Andronico MP, editor. Men in Groups: Insights, Interventions, and Psychoeducational Work.
Callaghan RC, Cunningham JA. (2002). Gender differences in detoxification: Predictors of completion and re-admission. Journal of Substance Abuse Treatment.
Capraro RL. (2000). Why college men drink: Alcohol, adventure, and the paradox of masculinity. Journal of American College Health.
Carlat DJ, Camargo CAJ, Herzog DB. (1997). Eating disorders in males: A report on 135 patients. American Journal of Psychiatry.
Carlson N. (1981). Male client – female therapist. Personal and Guidance Journal.
Carter RE, Haynes LF, Back SE, Herrin AE, Brady KT, Leimberger JD, Sonne SC, Hubbard RL, Liepman MR. (2008). Improving the transition from residential to outpatient addiction treatment: Gender differences in response to supportive telephone calls. American Journal of Drug and Alcohol Abuse.
Case A, Paxson C. (2005). Sex differences in morbidity and mortality. Demography.
Casswell S, Pledger M, Hooper R. (2003). Socioeconomic status and drinking patterns in young adults. Addiction.
Castro FG, Proescholdbell RJ, Abeita L, Rodriguez D. (1999). Ethnic and cultural minority groups. McCrady BS, Epstein EE, editors. Addictions: A Comprehensive Guidebook.
Catalano RF, Haggerty KP, Fleming CB, Brewer DD, Gainey RR. (2002). Children of substance-abusing parents: Current findings from the Focus on Families project. McMahon RJ, Peters RD, editors. The Effects of Parental Dysfunction on Children.
Catalano SM. (2004). Criminal Victimization, 2003.
Cates JA, Markley J. (1992). Demographic, clinical, and personality variables associated with male prostitution by choice. Adolescence.
Caulkins JP, Renter P. (1998). What price data tells us about drug markets. Journal of Drug Issues.
Center for Mental Health Services, National GAINS Center for Systemic Change for Justice-Involved Persons with Mental Illness. (2007). Sensitizing Providers to the Effects of Incarceration on Treatment and Risk Management (SPECTRM): Expanding the Mental Health Workforce Response to Justice-Involved Persons With Mental Illness.
Center for Substance Abuse Prevention. (2000). Communication Strategy Guide: A Look at Methamphetamine Use Among Three Populations.
Center for Substance Abuse Treatment. (1993). Improving Treatment for Drug-Exposed Infants.
Center for Substance Abuse Treatment. (1993). Pregnant, Substance-Using Women.
Center for Substance Abuse Treatment. (1993). Screening for Infectious Diseases Among Substance Abusers.
Center for Substance Abuse Treatment. (1994). Practical Approaches in the Treatment of Women Who Abuse Alcohol and Other Drugs.
Center for Substance Abuse Treatment. (1994). Simple Screening Instruments for Outreach for Alcohol and Other Drug Abuse and Infectious Diseases.
Center for Substance Abuse Treatment. (1995). Alcohol and Other Drug Screening of Hospitalized Trauma Patients.
Center for Substance Abuse Treatment. (1995). Combining Alcohol and Other Drug Treatment With Diversion for Juveniles in the Justice System.
Center for Substance Abuse Treatment. (1995). Developing State Outcomes Monitoring Systems for Alcohol and Other Drug Abuse Treatment.
Center for Substance Abuse Treatment. (1995). The Role and Current Status of Patient Placement Criteria in the Treatment of Substance Use Disorders.
Center for Substance Abuse Treatment. (1995). The Tuberculosis Epidemic: Legal and Ethical Issues for Alcohol and Other Drug Abuse Treatment Providers.
Center for Substance Abuse Treatment. (1996). Treatment Drug Courts: Integrating Substance Abuse Treatment With Legal Case Processing.
Center for Substance Abuse Treatment. (1997). A Guide to Substance Abuse Services for Primary Care Clinicians.
Center for Substance Abuse Treatment. (1997). Substance Abuse Treatment and Domestic Violence.
Center for Substance Abuse Treatment. (1998). Comprehensive Case Management for Substance Abuse Treatment.
Center for Substance Abuse Treatment. (1998). Continuity of Offender Treatment for Substance Use Disorders From Institution to Community.
Center for Substance Abuse Treatment. (1998). Naltrexone and Alcoholism Treatment.
Center for Substance Abuse Treatment. (1998). Substance Abuse Among Older Adults.
Center for Substance Abuse Treatment. (1998). Substance Use Disorder Treatment for People With Physical and Cognitive Disabilities.
Center for Substance Abuse Treatment. (1999). Brief Interventions and Brief Therapies for Substance Abuse.
Center for Substance Abuse Treatment. (1999). Enhancing Motivation for Change in Substance Abuse Treatment.
Center for Substance Abuse Treatment. (1999). Screening and Assessing Adolescents for Substance Use Disorders.
Center for Substance Abuse Treatment. (1999). Treatment of Adolescents With Substance Use Disorders.
Center for Substance Abuse Treatment. (1999). Treatment for Stimulant Use Disorders.
Center for Substance Abuse Treatment. (2000). Integrating Substance Abuse Treatment and Vocational Services.
Center for Substance Abuse Treatment. (2000). Substance Abuse Treatment for Persons With Child Abuse and Neglect Issues.
Center for Substance Abuse Treatment. (2000). Substance Abuse Treatment for Persons With HIV/AIDS.
Center for Substance Abuse Treatment. (2001). A Provider's Introduction to Substance Abuse Treatment for Lesbian, Gay, Bisexual, and Transgender Individuals.
Center for Substance Abuse Treatment. (2004). Clinical Guidelines for the Use of Buprenorphine in the Treatment of Opioid Addiction.
Center for Substance Abuse Treatment. (2004). Substance Abuse Treatment and Family Therapy.
Center for Substance Abuse Treatment. (2005). Medication-Assisted Treatment for Opioid Addiction in Opioid Treatment Programs.
Center for Substance Abuse Treatment. (2005). Substance Abuse Treatment for Adults in the Criminal Justice System.
Center for Substance Abuse Treatment. (2005). Substance Abuse Treatment for Persons With Co-Occurring Disorders.
Center for Substance Abuse Treatment. (2005). Substance Abuse Treatment: Group Therapy.
Center for Substance Abuse Treatment. (2006). Detoxification and Substance Abuse Treatment.
Center for Substance Abuse Treatment. (2006). Substance Abuse: Administrative Issues in Intensive Outpatient Treatment.
Center for Substance Abuse Treatment. (2006). Substance Abuse: Clinical Issues in Intensive Outpatient Treatment.
Center for Substance Abuse Treatment. (2008). An introduction to mutual support groups for alcohol and drug abuse. Substane Abuse in Brief Fact Sheet.
Center for Substance Abuse Treatment. (2008). Managing Depressive Symptoms in Substance Abuse Clients During Early Recovery.
Center for Substance Abuse Treatment. (2009). Addressing Suicidal Thoughts and Behaviors in Substance Abuse Treatment.
Center for Substance Abuse Treatment. (2009). Incorporating Alcohol Pharmacotherapies Into Medical Practice.
Center for Substance Abuse Treatment. (2009). Substance Abuse Treatment: Addressing the Specific Needs of Women.
Center for Substance Abuse Treatment. (2009). Supervision and the Professional Development of the Substance Abuse Counselor.
Center for Substance Abuse Treatment. (2010). Protracted withdrawal. Substance Abuse Treatment Advisory.
Center for Substance Abuse Treatment. (2010). Treating clients with traumatic brain injury. Substance Abuse Treatment Advisory.
Centers for Disease Control and Prevention. (2004). Cigarette Smoking Among Adults—United States, 2002. Morbidity and Mortality Weekly Report.
Centers for Disease Control and Prevention. (2008). Alcohol-attributable deaths and years of potential life lost among American Indians and Alaska Natives—United States, 2001–2005. Morbidity and Mortality Weekly Report.
Centers for Disease Control and Prevention. (2008). HIV/AIDS Surveillance Report, 2006.
Centers for Disease Control and Prevention. (2009). HIV/AIDS Surveillance Report, 2007.
Centers for Disease Control and Prevention, National Center for Injury Prevention and Control. (2009). WISQARS Injury Mortality Reports, 1999–2006.
Chae DH, Takeuchi DT, Barbeau EM, Bennett GG, Lindsey JC, Stoddard AM, Krieger N. (2008). Alcohol disorders among Asian Americans: Associations with unfair treatment, racial/ethnic discrimination, and ethnic identification (The National Latino and Asian Americans Study, 2002–2003. Journal of Epidemiology and Community Health.
Chan KS, Wenzel S, Orlando M, Montagnet C, Mandell W, Becker K, Ebener P. (2004). How important are client characteristics to understanding treatment process in the therapeutic community?. American Journal of Drug and Alcohol Abuse.
Chaney EF, Roszell DK, Cummings C. (1982). Relapse in opiate addicts: A behavioral analysis. Addictive Behaviors.
Chang P. (2000). Treating Asian/Pacific American addicts and their families. Krestan JA, editor. Bridges to Recovery: Addiction, Family Therapy, and Multicultural Treatment.
Chang T, Subramaniam PR. (2008). Asian and Pacific Islander American men's help-seeking: Cultural values and beliefs, gender roles, and racial stereotypes. International Journal of Men's Health.
Chaplin TM, Hong K, Bergquist K, Sinha R. (2008). Gender differences in response to emotional stress: An assessment across subjective, behavioral, and physiological domains and relations to alcohol craving. Alcoholism: Clinical and Experimental Research.
Chappel JN. (2003). Spiritual components of the recovery process. Graham AW, Wilford BB, editors. Principles of Addiction Medicine.
Chase KA, O'Farrell TJ, Murphy CM, Fals-Stewart W, Murphy M. (2003). Factors associated with partner violence among female alcoholic patients and their male partners. Journal of Studies and Alcohol.
Chemtob CM, Hamada RS, Roitblat HL, Muraoka MY. (1994). Anger, impulsivity, and anger control in combat-related posttraumatic stress disorder. Journal of Consulting and Clinical Psychology.
Chermack ST, Fuller BE, Blow FC. (2000). Predictors of expressed partner and non-partner violence among patients in substance abuse treatment. Drug and Alcohol Dependence.
Cherpitel CJ, Borges GL, Wilcox HC. (2004). Acute alcohol use and suicidal behavior: A review of the literature. Alcoholism: Clinical and Experimental Research.
Cherry DK, Woodwell DA. (2002). National Ambulatory Medical Care Survey: 2000 Summary.
Chi I, Lubben JE, Kitano HH. (1989). Differences in drinking behavior among three Asian American groups. Journal of Studies on Alcohol.
Christakis NA, Fowler JH. (2008). The collective dynamics of smoking in a large social network. New England Journal of Medicine.
Christensen RC, Hodgkins CC, Estlund K, Miller MD, Garces L. Prevalence of Trauma in Homeless Men With Co-Occurring Disorders. Poster presented at Complexities of Co-Occurring Conditions: Harnessing Services Research to Improve Care for Mental, Substance Use, and Medical/Physical Disorders.
Chuick CD, Greenfeld JM, Greenberg ST, Shepard SJ, Cochran SV, Haley JT. (2009). A qualitative investigation of depression in men. Psychology of Men & Masculinity.
Clark R, Anderson NB, Clark VR, Williams DR. (1999). Racism as a stressor for African Americans: A biopsychosocial model. American Psychologist.
Cochran BN, Cauce AM. (2006). Characteristics of lesbian, gay, bisexual, and transgender individuals entering substance abuse treatment. Journal of Substance Abuse Treatment.
Cochran SA. (2001). Assessing and treating depression in men. Brooks GR, Good GE, editors. The New Handbook of Psychotherapy and Counseling With Men: A Comprehensive Guide to Settings, Problems, and Treatment Approaches.
Cochran SD, Keenan C, Schober C, Mays VM. (2000). Estimates of alcohol use and clinical treatment needs among homosexually active men and women in the U.S. population. Journal of Consulting and Clinical Psychology.
Cochran SV. (2005). Evidence-based assessment with men. Journal of Clinical Psychology.
Cohen JB, Dickow A, Horner K, Zweben JE, Balabis J, Vandersloot D, Reiber C. (2003). Abuse and violence history of men and women in treatment for methamphetamine dependence. The American Journal on Addictions.
Cole SW, Kemeny ME, Taylor SE, Visscher BR. (1996). Elevated physical health risk among gay men who conceal their homosexual identity. Health Psychology.
Collins GB, McAllister MS, Ford DB. (2007). Patient-provider e-mail communication as an adjunctive tool in addiction medicine. Journal of Addictive Diseases.
Collison M. (1996). In search of the high life: Drugs, crime, masculinities and consumption. British Journal of Criminology.
Colon E. (1998). Alcohol use among Latino males: Implications for the development of culturally competent prevention and treatment services. Alcoholism Treatment Quarterly.
Compton WM, Cottler LB, Ben Abdallah A, Phelps DL, Spitznagel EL, Horton JC. (2000). Substance dependence and other psychiatric disorders among drug dependent subjects: Race and gender correlates. American Journal on Addiction.
Connors GJ, Walitzer KS, Tonigan JS. (2008). Spiritual change in recovery. Research on Alcoholics Anonymous and Spirituality in Addiction Recovery: Recent Developments in Alcoholism.
Conway KP, Compton W, Stinson FS, Grant BF. (2006). Lifetime comorbidity of DSM-IV mood and anxiety disorders and specific drug use disorders: Results from the National Epidemiologic Survey on Alcohol and Related Conditions. Journal of Clinical Psychiatry.
Cook DR. (2000). Internalized Shame Scale.
Cook TAR, Luczak SE, Shea SH, Ehlers CL, Carr LG, Wall TL. (2005). Associations of ALDH2 and ADH1B genotypes with response to alcohol in Asian Americans. Journal of Studies on Alcohol.
Cooper C, Eslinger D, Nash D, Al Zawahri J, Stolley P. (2000). Repeat victims of violence: Report of a large concurrent case-control study. Archives of Surgery.
Cooper A, Morahan-Martin J, Mathy RM, Maheu M. (2002). Toward an increased understanding of user demographics in online sexual activities. Journal of Sex and Marital Therapy.
Cooper A, Galbreath N, Becker MA. (2004). Sex on the internet: Furthering our understanding of men with online sexual problems. Psychology of Addictive Behaviors.
Copenhaver MM, Lash SJ, Eisler RM. (2000). Masculine gender-role stress, anger, and male intimate abusiveness: Implications for men's relationships. Sex Roles.
Copes H, Hochstetler A. (2003). Situational construction of masculinity among male street thieves. Journal of Contemporary Ethnography.
Corbett K, Mora J, Ames G. (1991). Drinking patterns and drinking-related problems of Mexican American husbands and wives. Journal of Studies on Alcohol.
Cottler LB, Nishith P, Compton WM. (2001). Gender differences in risk factors for trauma exposure and posttraumatic stress disorder among inner-city drug abusers in and out of treatment. Comprehensive Psychiatry.
Coulson C, Ng F, Geertsema M, Dodd S, Berk M. (2009). Client-reported reasons for non-engagement in drug and alcohol treatment. Drug and Alcohol Review.
Courtenay WH. (1998). College men's health: An overview and a call to action. Journal of American College Health.
Courtenay WH. (2000). Constructions of masculinity and their influence on men's well-being: A theory of gender and health. Social Science and Medicine.
Courtenay WH. (2003). Key determinants of the health and well-being of men and boys. International Journal of Men's Health.
Courtenay WH, McCreary DR, Merighi JR. (2002). Gender and ethnic differences in health beliefs and behaviors. Journal of Health Psychology.
Cowan J, Devine C. (2008). Food, eating, and weight concerns of men in recovery from substance addiction. Appetite.
Coxell A, King M, Mezey G, Gordon D. (1999). Lifetime prevalence, characteristics, and associated problems of non-consensual sex in men: Cross sectional survey. British Medical Journal.
Craddock A, Collins JJ, Timrots A. (1994). Fact Sheet: Drug-Related Crime.
Crits-Christoph P, Siqueland L, Blaine J, Frank A, Luborsky L, Onken LS, Muenz LR, Thase ME, Weiss RD, Gastfriend DR, Woody GE, Barber JP, Butler SF, Daley D, Salloum I, Bishop S, Najavits LM, Lis J, Mercer D, Griffin ML, Moras K, Beck AT. (1999). Psychosocial treatments for cocaine dependence: National Institute on Drug Abuse Collaborative Cocaine Treatment Study. Archives of General Psychiatry.
Crocker J, Major B. (1989). Social stigma and self-esteem: The self-protective properties of stigma. Psychological Review.
Crosby GM, Stall RD, Paul JP, Barrett DC. (1998). Alcohol and drug use patterns have declined between generations of younger gay-bisexual men in San Francisco. Drug and Alcohol Dependence.
Crosby R, DiClemente RJ. (2004). Use of recreational Viagra among men having sex with men. Sexually Transmitted Infections.
Crum RM. (2003). The epidemiology of addictive disorders. Graham AW, Schultz TK, Mayo-Smith MF, Ries RK, Wilford BB, editors. Principles of Addiction Medicine.
Cunradi CB, Caetano R, Schafer J. (2002). Alcohol-related problems, drug use, and male intimate partner violence severity among U.S. couples. Alcoholism: Clinical and Experimental Research.
Curtis KM, Savitz DA, Arbuckle TE. (1997). Effects of cigarette smoking, caffeine consumption, and alcohol intake on fecundability. American Journal of Epidemology.
Czuchry M, Dansereau D. (2003). A model of the effects of node-link mapping on drug abuse counseling. Addictive Behaviors.
Darke S, Ross J. (2002). Suicide among heroin users: Rates, risk factors and methods. Addiction.
Davis KC, Schraufnagel TJ, George WH, Norris J. (2008). The use of alcohol and condoms during sexual assault. American Journal of Men's Health.
Dawson G. (1997). The African American male: Brief insights on health, drugs, and incarceration. Part 1. Journal of the National Medical Association.
Dearing RL, Stuewig J, Tangney JP. (2005). On the importance of distinguishing shame from guilt: Relations to problematic alcohol and drug use. Addictive Behaviors.
Dees SM, Dansereau DF. (1993). Using schematic organizers to help college students organize personal concepts and behavior related to alcohol and cocaine use. Addictive Behaviors.
Dees SM, Dansereau DF. (2000). TCU Guide Maps: A Resource for Counselors.
Degenhardt L, Chiu WT, Sampson N, Kessler RC, Anthony J. (2007). Epidemiological patterns of extra-medical drug use in the United States: Evidence from the National Comorbidity Survey Replication, 2001–2003. Drug and Alcohol Dependence.
DeMaria R, Weeks G, Hof L. (1999). Focused Genograms: Intergenerational Assessment of Individuals, Couples, and Families.
de Miranda J. (1999). Treatment services offer limited access for people with disabilities. The Counselor.
de Miranda J. Testimony for the ABA/Join Together Policy Panel Hearing on Discrimination Against Individuals in Treatment Recovery. Manuscript presented at Medication Prohibitions as a Barrier to Treatment Access.
Department of Veterans Affairs, Office of Congressional and Legislative Affairs. (2001). Statement of Thomas L. Garthwaite, MD, Under Secretary for Health, Veterans Health Administration, Before the Subcommittee on Health Committee on Veterans' Affairs, U.S. House of Representatives, June 20, 2001.
Dhaliwal GK, Gauzas L, Antonowicz DH, Ross RR. (1996). Adult male survivors of childhood sexual abuse: Prevalence, sexual abuse characteristics, and long-term effects. Clinical Psychology Review.
Dick DM, Foroud T. (2003). Candidate genes for alcohol dependence: A review of genetic evidence from human studies. Alcoholism: Clinical and Experimental Research.
Dienhart A. (2001). Engaging men in family therapy: Does the gender of the therapist make a difference?. Journal of Family Therapy.
Dienhart A, Avis JM. (1994). Working with men in family therapy: An exploratory study. Journal of Marital and Family Therapy.
Dietz TL. (2007). Predictors of reported current and lifetime substance abuse problems among a national sample of U.S. homeless. Substance Use & Misuse.
Dixon L, Adler D, Braun D, Dulit R, Goldman B, Siris S, Sonis W, Bank P, Hermann R, Fornari V, Grant J. (2001). Reexamination of therapist self-disclosure. Psychiatric Services.
Dobkin PL, Tremblay RE, Sacchitelle C. (1997). Predicting boys' early-onset substance abuse from father's alcoholism, son's disruptiveness, and mother's parenting behavior. Journal of Consulting and Clinical Psychology.
Donovan B, Padin-Rivera E, Kowaliw S. (2001). Transcend: Initial outcomes from a posttraumatic stress disorder/substance abuse treatment program. Journal of 'Traumatic Stress.
Dooley D, Prause J. (1998). Underemployment and alcohol misuse in the National Longitudinal Survey of Youth. Journal of Studies on Alcohol.
Dore J. (1994). A model of time-limited group therapy for men: Its use with recovering addicts. Group for Recovering Addicts.
Doweiko HE. (2002). Concepts of Chemical Dependency.
Downs WR, Smyth NJ, Miller BA. (1996). Relationship between childhood violence and alcohol problems among men who batter: An empirical review and synthesis. Aggression and Violent Behavior.
Drug Enforcement Administration. (2004). Steroid Abuse in Today's Society: A Guide for Understanding Steroids and Related Substances.
Dube SR, Anda RF, Felitti VJ, Chapman DP, Williamson DF, Giles WH. (2001). Childhood abuse, household dysfunction, and the risk of attempted suicide throughout the life span: Findings from the Adverse Childhood Experiences Study. The Journal of the American Medical Association.
Duck W. (2009). Black male sexual politics: Avoidance of HIV/AIDS testing as a masculine health practice. Journal of African American Studies.
Dunlap E, Johnson BD, Kotarba J, Fackler J. (2009). Making connections: New Orleans evacuees' experiences in obtaining drugs. Journal of Psychoactive Drugs.
Easton C, Swan S, Sinha R. (2000). Motivation to change substance use among offenders of domestic violence. Journal of Substance Abuse Treatment.
Eaton WW, Kramer M, Anthony JC, Dryman A, Shapiro S, Locke BZ. (1989). The incidence of specific DIS/DSM-III mental disorders: Data from the NIMH Epidemiologic Catchment Area Program. Acta Psychiatrica Scandinavica.
Egeland B, Jacobvitz D, Sroufe LA. (1988). Breaking the cycle of abuse. Child Development.
Eiden RD, Edwards EP, Leonard KE. (2002). Mother-infant and father-infant attachment among alcoholic families. Development and Psychopathology.
Eisler RM. (1995). The relationship between masculine gender role stress and men's health risk: The validation of a construct. Levant RF, Pollack WS, editors. A New Psychology of Men.
Eisler RM, Skidmore JR. (1987). Masculine gender role stress: Scale development and component factors in the appraisal of stressful situations. Behavior Modification.
Eisler RM, Skidmore JR, Ward CH. (1988). Masculine gender role stress: Predictor of anger, anxiety, and health-risk behaviors. Journal of Personality Assessment.
Elbogen EB, Swanson JW, Swartz MS, Wagner HR. (2003). Characteristics of third-party money management for persons with psychiatric disabilities. Psychiatric Services.
Emanuele MA, Emanuele N. (2001). Alcohol and the male reproductive. system Alcohol Research and Health.
EMERGE. (1995). Guidelines for talking to abusive husbands. Domestic Violence: The Alcohol and Other Drug Connection.
Epstein EE, McCrady BS, Morgan TJ, Cook SM, Kugler G, Ziedonis D. (2007). Couples treatment for drug-dependent males: Preliminary efficacy of a standalone outpatient model. Addictive Disorders & Their Treatment.
Epstein J, Barker P, Vorburger M, Murtha C. (2004). Serious Mental Illness and Its Co-Occurrence With Substance Use Disorders: 2002.
Ersche KD, Clark L, London M, Robbins TW, Sahakian BJ. (2006). Profile of executive and memory function associated with amphetamine and opiate dependence. Neuropsychopharmacology.
Etheridge RM, Hubbard RL, Anderson J, Craddock SG, Flynn PM. (1997). Treatment structure and program services in the Drug Abuse Treatment Outcome Study (DATOS). Psychology of Addictive Behavior.
Evren C, Sar V, Evren B, Semiz U, Dalbudak E, Cakmak D. (2008). Dissociation and alexithymia among men with alcoholism. Psychiatry and Clinical Neurosciences.
Ewing R. (2001). Profile of Clinicians in the National Treatment Improvement Evaluation Study (NTIES).
(2001). Fagan J, Hawkins AJ, editors. Clinical and Educational Interventions With Fathers.
Falck RS, Wang J, Carlson RG. (2008). Among long-term crack smokers, who avoids and who succumbs to cocaine addiction?. Drug and Alcohol Dependence.
Falck RS, Wang J, Siegal HA, Carlson RG. (2004). The prevalence of psychiatric disorder among a community sample of crack cocaine users: An exploratory study with practical implications. Journal of Nervous & Mental Disease.
Falicov CJ. (2005). Mexican Families. McGoldrick M, Giordano J, Garcia-Preto N, editors. Ethnicity and Family Therapy.
Fallot RD, Harris M, Affolter HU, Anglin J, Arledge E, Bebout R, Dende J, Freeman D, Green W, Lee M. (2001). Men's Trauma Recovery and Empowerment Model (M-TREM): A Clinician's Guide to Working With Male Trauma Survivors in Groups.
Fals-Stewart W. (2003). The occurrence of partner physical aggression on days of alcohol consumption: A longitudinal diary study. Journal of Consulting and Clinical Psychology.
Fals-Stewart W, Birchler GR. (2001). A national survey of the use of couples therapy in substance abuse treatment. Journal of Substance Abuse Treatment.
Fals-Stewart W, Birchler GR, O'Farrell TJ. (1999). Drug-abusing patients and their intimate partners: Dyadic adjustment, relationship stability, and substance use. Journal of Abnormal Psychology.
Fals-Stewart W, Golden J, Schumacher JA. (2003). Intimate partner violence and substance use: A longitudinal day-to-day examination. Addictive Behaviors.
Fals-Stewart W, Klostermann K, Yates BT, O'Farrell TJ, Birchler GR. (2005). Brief relationship therapy for alcoholism: A randomized clinical trial examining clinical efficacy and cost-effectiveness. Psychology of Addictive Behaviors.
Fals-Stewart W, O'Farrell TJ. (2003). Behavioral family counseling and naltrexone for male opioid-dependent patients. Journal of Consulting and Clinical Psychology.
Fals-Stewart W, O'Farrell TJ, Feehan M, Birchler GR, Tiller S, McFarlin SK. (2000). Behavioral couples therapy versus individual-based treatment for male substance-abusing patients: An evaluation of significant individual change and comparison of improvement rates. Journal of Substance Abuse Treatment.
Fals-Stewart W, O'Farrell TJ, Freitas TT, McFarlin SK, Rutigliano P. (2000). The timeline followback reports of psychoactive substance use by drug-abusing patients: Psychometric properties. Journal of Consulting and Clinical Psychology.
Farber BA. (2003). Patient self-disclosure: A review of the research. Journal of Clinical Psychology.
Farber BA, Hall D. (2002). Disclosure to therapists: What is and is not discussed in psychotherapy. Journal of Clinical Psychology.
Farley M, Golding JM, Young G, Mulligan M, Minkoff JR. (2004). Trauma history and relapse probability among patients seeking substance abuse treatment. Journal of Substance Abuse Treatment.
Felix-Ortiz M, Abreu JM, Briano M, Bowen D. (2001). A critique of machismo measures in psychological research. Advances in Psychology Research.
Fernandez AC, Begley EA, Marlatt GA. (2006). Family and peer interventions for adults: Past approaches and future directions. Psychology of Addictive Behaviors.
Fernandez E, Scott S. (2009). Anger treatment in chemically-dependent inpatients: Evaluation of phase effects and gender. Behavioural and Cognitive Psychotherapy.
Finlayson RE. (1995). Misuse of prescription drugs. International Journal of the Addictions.
Finn PR, Sharkansky EJ, Viken R, West TL, Sandy J, Bufferd GM. (1997). Heterogeneity in the families of sons of alcoholics: The impact of familial vulnerability type on offspring characteristics. Journal of Abnormal Psychology.
Finney JW, Hahn AC, Moos RH. (1996). The effectiveness of inpatient and outpatient treatment for alcohol abuse: The need to focus on mediators and moderators of setting effects. Addiction.
Fiorentine R. (1999). After drug treatment: Are 12-Step programs effective in maintaining abstinence?. American Journal of Drug and Alcohol Abuse.
Fiorentine R, Anglin MD. (1997). Does increasing the opportunity for counseling increase the effectiveness of outpatient drug treatment?. American Journal of Drug and Alcohol Abuse.
Fiorentine R, Anglin MD, Gil-Rivas V, Taylor E. (1997). Drug treatment: Explaining the gender paradox. Substance Use and Misuse.
Fiorentine R, Hillhouse MP. (2000). Drug treatment and 12-Step program participation: The additive effects of integrated recovery activities. Journal of Substance Abuse Treatment.
Fiorentine R, Hillhouse MP. (1999). Drug treatment effectiveness and client-counselor empathy: Exploring the effects of gender and ethnic congruency. Journal of Drug Issues.
Fiorentine R, Nakashima J, Anglin MD. (1999). Client engagement in drug treatment. Journal of Substance Abuse Treatment.
Flynn PM, Joe GW, Broome KM, Simpson DD, Brown BS. (2003). Recovery from opioid addiction in DATOS. Journal of Substance Abuse Treatment.
Foote JA, Harris RB, Gilles ME, Ahner H, Roice D, Becksted T, Messinger T, Bunch R, Bilant K. (1996). Physician advice and tobacco use: A survey of lst-year college students. Journal of American College Health.
Foran HM, O'Leary KD. (2008). Alcohol and intimate partner violence: A meta-analytic review. Clinical Psychology Review.
Forbes D, Creamer M, Hawthorne G, Allen N, McHugh T. (2003). Comorbidity as a predictor of symptom change after treatment in combat-related posttraumatic stress disorder. Journal of Nervous and Mental Disease.
Forbes D, Parslow R, Creamer M, Allen N, McHugh T, Hopwood M. (2008). Mechanisms of anger and treatment outcome in combat veterans with posttraumatic stress disorder. Journal of Traumatic Stress.
Forrest GG. (1994). Chemical Dependency and Antisocial Personality Disorder: Psychotherapy and Assessment Strategies.
Forrest GG. (2010). Self-Disclosure in Psychotherapy and Recovery.
Fortenberry JD, McFarlane M, Bleakley A, Bull S, Fishbein M, Grimley D.M, Malotte CK, Stoner BP. (2002). Relationships of stigma and shame to gonorrhea and HIV screening. American Journal of Public Health.
Fowler IL, Carr VJ, Carter NT, Lewin TJ. (1998). Patterns of current and lifetime substance use in schizophrenia. Schizophrenia Bulletin.
Fracher JC, Kimmel MS. (1987). Hard issues and soft spots: Counseling men about sexuality. Scher M, Stevens M, editors. Handbook of Counseling and Psychotherapy With Men.
Fragoso JM, Kashubeck S. (2000). Machismo, gender role conflict, and mental health in Mexican American men. Psychology of Men and Masculinity.
Frank JB, Weihs K, Minerva E, Lieberman DZ. (1998). Women's mental health in primary care: Depression, anxiety, somatization, eating disorders, and substance abuse. Medical Clinics of North America.
Freeman-Longo RE, Blanchard GT. (1998). Sexual Abuse in America: Epidemic of the 21st Century.
French MT, McCollister KE, Sacks S, McKendrick K, De Leon G. (2002). Benefit-cost analysis of a modified therapeutic community for mentally ill chemical abusers. Evaluation and Program Planning.
French MT, Salome HJ, Krupski A, McKay JR, Donovan DM, McLellan AT, Durell J. (2000). Benefit-cost analysis of residential and outpatient addiction treatment in the State of Washington. Evaluation Review.
Friedman AS. (1998). Substance use/abuse as a predictor to illegal and violent behavior: A review of the relevant literature. Aggression and Violent Behavior.
Friedman AS, Granick S, Bransfield S, Kreisher C, Schwartz A. (1996). The consequences of drug use/abuse for vocational career: A longitudinal study of a male urban African American sample. American Journal of Drug and Alcohol Abuse.
Friedman MJ, Schnurr PP, McDonagh-Coyle A. (1994). Posttraumatic stress disorder in the military veteran. Psychiatric Clinics of North America.
Friedmann PD, Lemon SC, Stein MD, Etheridge RM, D'Aunno TA. (2001). Linkage to medical services in the Drug Abuse Treatment Outcome Study. Medical Care.
Friedmann PD, Phillips KA, Saitz R, Samet JH. (2009). Linking addiction treatment with other medical and psychiatric treatment systems. Ries RK, Fiellin DA, Miller SC, Saitz R, editors. Principles of Addiction Medicine.
Friedmann PD, Zhang Z, Hendrickson J, Stein MD, Gerstein DR. (2003). Effect of primary medical care on addiction and medical severity in substance abuse treatment programs. Journal of General Internal Medicine.
Frost JC. (1998). Countertransference considerations for the gay male when leading psychotherapy groups for gay men. International Journal of Group Psychotherapy.
Frueh BC, Elhai JD, Grubaugh AL, Monnier J, Kashdan TB, Sauvageot JA, Hamner MB, Burkett BG, Arana GW. (2005). Documented combat exposure of U.S. veterans seeking treatment for combat-related post-traumatic stress disorder. British Journal of Psychiatry.
Fu Q, Heath AC, Bucholz KK, Lyons MJ, Tsuang MT, True WR, Eisen SA. (2007). Common genetic risk of major depression and nicotine dependence: The contribution of antisocial traits in a United States veteran male twin cohort. Twin Research and Human Genetics.
Gaes GG, Goldberg AL. (2004). Prison Rape: A Critical Review of the Literature, Working Paper.
Galanter M, Dermatis H, Glickman L, Maslansky R, Sellers MB, Neumann E, Rahman-Dujarric C. (2004). Network therapy: Decreased secondary opioid use during buprenorphine. maintenance Journal of Substance Abuse Treatment.
Galanter M, Dermatis H, Keller D, Trujillo M. (2002). Network therapy for cocaine abuse: Use of family and peer supports. The American Journal on Addictions.
Galanter M, Spiro HR, Hohl PC, Dobbs-Wiggins PC, Harding GT, Barnhouse RT, Thurrell RJ, Tuyl CV. (1989). Guidelines Regarding Possible Conflict Between Psychiatrists' Religious Commitments and Psychiatric Practice.
Galen LW, Brower KJ, Gillespie BW, Zucker RA. (2000). Sociopathy, gender and treatment outcome among outpatient substance abusers. Drug and Alcohol Dependence.
(1998). Garfinkel I, McLanahan SS, Meyer DR, Seltzer JA, editors. Fathers Under Fire: The Revolution in Child Support Enforcement.
Garrett J, Landau J, Shea R, Stanton MD, Baciewicz G, Brinkman-Sull D. (1998). The ARISE Intervention: Using family and network links to engage addicted persons in treatment. Journal of Substance Abuse Treatment.
Garrett J, Landau-Stanton J, Stanton MD, Stellato-Kabat J, Stellato-Kabat D. (1997). ARISE (Albany-Rochester Interventional Sequence for Engagement): A method for engaging reluctant alcohol- and drug-dependent individuals in treatment. Journal of Substance Abuse Treatment.
Garrett J, Stanton MD, Landau J, Baciewicz G, Brinkman-Sull D, Shea R. (1999). The “concerned other” call: Using family links and networks to overcome resistance to addiction treatment. Substance Use and Misuse.
Gatrell J, Wood DW, Ovenden A. (2000). Substance Abuse in Hawaii: Adult Population Household Telephone Survey (1998).
Geisner IM, Larimer ME, Neighbors C. (2004). The relationship among alcohol use, related problems, and symptoms of psychological distress: Gender as a moderator in a college sample. Addictive Behaviors.
George MJ. (2003). Invisible touch. Aggression and Violent Behavior.
George WH, Davis KC, Schraufnagel TJ, Norris J, Heiman JR, Schacht RL, Stoner SA, Kajumulo KF. (2008). Later that night: Descending alcohol intoxication and men's sexual arousal. American Journal of Men's Health.
Gerson K. (2008). Moral dilemmas, moral strategies, and the transformation of gender: Lessons from two generations of work and family change. The Kaleidoscope of Gender: Prisms, Patterns, and Possibilities.
Giancola PR. (2002). Irritability, acute alcohol consumption and aggressive behavior in men and women. Drug and Alcohol Dependence.
Giancola PR. (2002). The influence of trait anger on the alcohol-aggression relation in men and women. Alcoholism: Clinical and Experimental Research.
Giancola PR, Zeichner A. (1995). An investigation of gender differences in alcohol-related aggression. Journal of Studies on Alcohol.
Gilmore DD. (1990). Manhood in the Making: Cultural Concepts of Masculinity.
Ginsberg BG. (1996). Together in group therapy: Fathers and their adolescent sons. Andronico MP, editor. Men in Groups: Insights, Interventions, and Psychoeducational Work.
Giordano J, McGoldrick M. (2005). Families of European origin: An overview. McGoldrick M, Giordano J, Garcia-Preto N, editors. Ethnicity and Family Therapy.
Glaxo SmithKline New Zealand. (2005). Methadone Syrup: Glaxo Smith Kline Information for Health Professionals Data Sheet.
Goldstein JM, Cohen LS, Horton NJ, Lee H, Andersen S, Tohen M, Crawford A, Tollefson G. (2002). Sex differences in clinical response to olanzapine compared with haloperidol. Psychiatry Research.
Gomberg ESL. (1992). Medication problems and drug abuse. Turner FJ, editor. Mental Health and the Elderly.
Good GE, Borst TS, Wallace DL. (1994). Masculinity research: A review and critique. Applied and Preventive Psychology.
Good GE, Dell DM, Mintz LB. (1989). Male role and gender role conflict: Relations to help-seeking in men. Journal of Counseling Psychology.
Good GE, Mintz LB. (1990). Gender role conflict and depression in college men: Evidence for compounded risk. Journal of Counseling and Development.
Good GE, Robertson JM, Fitzgerald LF, Stevens M. (1996). The relation between masculine role conflict and psychological distress in male university counseling center clients. Journal of Counseling and Development.
Good GE, Sherrod NB. (1997). Men's resolution of nonrelational sex across the lifespan. Levant RF, Brooks GR, editors. Men and Sex: New Psychological Perspectives.
Good GE, Sherrod NB. (2001). Men's problems and effective treatments: Theory and empirical support. Brooks GR, Good GE, editors. The New Handbook of Psychotherapy and Counseling With Men: A Comprehensive Guide to Settings, Problems, and Treatment Approaches.
Good GE, Sherrod NB, Dillon MG. (2000). Masculine gender role stressors and men's health. Eisler RM, Hersen M, editors. Handbook of Gender, Culture, and Health.
Good GE, Thomson DA, Brathwaite AD. (2005). Men and therapy: Critical concepts, theoretical frameworks, and research recommendations. Journal of Clinical Psychology.
Good GE, Wood PK. (1995). Male gender role conflict, depression, and help seeking: Do college men face double jeopardy?. Journal of Counseling and Development.
Goodman LA, Salyers MP, Mueser KT, Rosenberg SD, Swartz M, Essock SM, Osher FC, Butterfield MI, Swanson J. (2001). Recent victimization in women and men with severe mental illness: Prevalence and correlates. Journal of Traumatic Stress.
Gorey KM, Leslie DR. (1997). The prevalence of child sexual abuse: Integrative review adjustment for potential response and measurement biases. Child Abuse and Neglect.
Gorman EM, Carroll RT. (2000). Substance abuse and HIV: Considerations with regard to methamphetamines and other recreational drugs for nursing practice and research. Journal of the Association of Nurses in AIDS Care.
Gorman EM, Nelson KR, Applegate T, Scrol A. (2004). Club drug and polysubstance abuse and HIV among gay/bisexual men: Lessons gleaned from a community study. Journal of Gay & Lesbian Social Services.
Gorsuch RL, Miller WR. (1999). Assessing spirituality. Miller WR, editor. Integrating Spirituality Into Treatment: Resources for Practitioners.
Gossop M, Stewart D, Browne N, Marsden J. (2002). Factors associated with abstinence, lapse or relapse to heroin use after residential treatment: Protective effect of coping responses. Addiction.
Gottheil E, Weinstein SP, Sterling RC, Lundy A, Serota RD. (1998). A randomized controlled study of the effectiveness of intensive outpatient treatment for cocaine dependence. Psychiatric Services.
Grant BF, Dawson DZ. (1997). Age at onset of alcohol use and its association with DSM-IV alcohol abuse and dependence: Results from the national longitudinal alcohol epidemiologic survey. Journal of Substance Abuse.
Grant BF, Dawson DA, Stinson FS, Chou SP, Dufour MC, Pickering RP. (2004). The 12-month prevalence and trends in DSM-IV alcohol abuse and dependence: United States, 1991–1992 and 2001–2002. Drug and Alcohol Dependence.
Grant BF, Goldstein RB, Chou SP, Huang B, Stinson FS, Dawson DA, Saha TD, Smith SM, Pulay AJ, Pickering RP, Ruan WJ, Compton WM. (2009). Sociodemographic and psychopathologic predictors of first incidence of DSM-IV substance use, mood and anxiety disorders: Results from the Wave 2 National Epidemiologic Survey on Alcohol and Related Conditions. Molecular Psychiatry.
Grant BF, Hasin DS, Stinson FS, Dawson DA, Chou SP, Ruan WJ, Pickering RP. (2004). Prevalence, correlates, and disability of personality disorders in the United States: Results from the National Epidemiologic Survey on Alcohol and Related Conditions. Journal of Clinical Psychiatry.
Grant BF, Stinson FS, Dawson DA, Chou SP, Ruan WJ. (2005). Co-occurrence of DSM-IV personality disorders in the United States: Results from the National Epidemiologic Survey on Alcohol and Related Conditions. Comprehensive Psychiatry.
Grant BF, Stinson FS, Dawson DA, Chou SP, Ruan WJ, Pickering RP. (2004). Co-occurrence of 12-month alcohol and drug use disorders and personality disorders in the United States. Archives of General Psychiatry.
Grant JE, Potenza MN. (2007). Textbook of Men's Mental Health.
Green B. (2003). Post-traumatic stress disorder: symptom profiles in men and women. Current Medical Research and Opinion.
Green CA, Polen MR, Lynch FL, Dickinson DM, Bennett MD. (2004). Gender differences in outcomes in an HMO-based substance abuse treatment program. Journal of Addictive Diseases.
Greenan DE, Tunnell G. (2003). Couple Therapy With Gay Men.
Greenfeld LA. (1997). Sex Offenses and Offenders: An Analysis of Data on Rape and Sexual Assault.
Greenfeld LA, Henneberg MA. (2001). Victim and offender self-reports of alcohol involvement in crime. Alcohol Research and Health.
Greenfeld LA, Rand MR, Craven D, Klaus PA, Perkins CA, Ringel C, Warchol G, Maston C, Fox JA. (1998). Violence by Intimates: Analysis of Data on Crimes by Current or Former Spouses, Boyfriends, and Girlfriends.
Grella CE, Greenwell L, Mays VM, Cochran SD. (2009). Influence of gender, sexual orientation, and need on treatment utilization for substance use and mental disorders: Findings from the California Quality of Life Survey. BMC Psychiatry.
Grella CE, Joshi V. (1999). Gender differences in drug treatment careers among clients in the national Drug Abuse Treatment Outcome Study. American Journal of Drug and Alcohol Abuse.
Grella CE, Karno MP, Warda US, Niv N, Moore AA. (2009). Gender and comorbidity among individuals with opioid use disorders in the NESARC study. Addictive Behaviors.
Grieco EM. (2001). The Native Hawaiian and Other Pacific Islander Population: Census 2000 Brief.
Grieco EM, Cassidy RC. (2001). Overview of Race and Hispanic Origin: Census 2000 Brief.
Grill E, Weitkunat R, Crispin A. (2001). Separation from children as a specific risk factor to fathers' health and lifestyles. Sozial- Und Praventivmedizin.
Grossman M. (2004). Individual Behaviors and Substance Use: The Role of Price.
Gunter TD, Arndt S, Wenman G, Allen J, Loveless P, Sieleni B, Black DW. (2008). Frequency of mental and addictive disorders among 320 men and women entering the Iowa prison system: Use of the MINI-Plus. Journal of the American Academy of Psychiatry and the Law.
(2002). Haack MR, Adger H, editors. Strategic Plan for Interdisciplinary Faculty Development: Arming the Nation's Health Professional Workforce for a New Approach to Substance Use Disorders.
Haas GL, Glick ID, Clarkin JF, Spencer JH, Lewis AB. (1990). Gender and schizophrenia outcome: A clinical trial of an inpatient family intervention. Schizophrenia Bulletin.
Halkitis PN, Mukherjee PP, Palamar JJ. (2009). Longitudinal modeling of methamphetamine use and sexual risk behaviors in gay and bisexual men. AIDS and Behavior.
Halkitis PN, Palamar JJ, Mukherjee PP. (2007). Poly-club-drug use among gay and bisexual men: A longitudinal analysis. Drug and Alcohol Dependence.
Halkitis PN, Solomon TM, Moeller RW, Doig SA, Espinosa LS, Siconolfi D, Homer BD. (2009). Methamphetamine use among gay, bisexual and non-identified men-who-have-sex-with-men: An analysis of daily patterns. Journal of Health Psychology.
Hall AS, Kelly KR. (1996). Noncustodial fathers in groups: Maintaining the parenting bond. Andronico MP, editor. Men in Groups: Insights, Interventions, and Psychoeducational Work.
Hall JA, Roter DL. (2002). Do patients talk differently to male and female physicians? A meta-analytic review. Patient Education and Counseling.
Halpern DF. (1997). Sex differences in intelligence: Implications for education. American Psychologist.
Hardy K. Plenary Address. Presented at the Dare to Act Post-Conference Institute: Men and Trauma, Renaissance Harborplace Hotel.
Hare RD. (1991). Manual for the Hare Psychopathy Checklist-Revised.
Harrison PM, Beck AJ. (2003). Prisoners in 2002: Bureau of Justice Statistics Bulletin.
Harrison PM, Karberg JC. (2004). Prison and Jail Inmates at Midyear 2003: Bureau of Justice Statistics Bulletin.
Hart SD, Kropp PR, Laws DR, Kalver J, Logan C, Watt KA. (2003). Risk for Sexual Violence Protocol (RSVP): Structured Professional Guidelines for Assessing Risk of Sexual Violence.
Harwood H, Fountain D, Carothers S, Gerstein D, Johnson R. (1998). Gender differences in the economic impacts of clients before, during and after substance abuse treatment. Drugs and Society.
Harwood HJ. (2002). Survey on behavioral health workplace. Frontlines: Linking Alcohol Services Research & Practice.
Hasin DS, Stinson FS, Ogburn E, Grant BF. (2007). Prevalence, correlates, disability, and comorbidity of DSM-IV alcohol abuse and dependence in the United States: Results from the National Epidemiologic Survey on Alcohol and Related Conditions. Archives of General Psychiatry.
Hassan I, McCabe R, Priebe S. (2007). Professional-patient communication in the treatment of mental illness: A review. Communication and Medicine.
Hastings G, Anderson S, Cooke E, Gordon R. (2005). Alcohol marketing and young people's drinking: A review of the research. Journal of Public Health Policy.
Hazelden Foundation. (2003). Twelve Step Recovery is Spirituality at Its Best: Alive & Free.
Heath DB. (1990). Cultural factors in the choice of drugs. Galanter M, editor. Recent Developments in Alcoholism: Combined Alcohol and Other Drug Dependence.
Heath DB. (2000). Drinking Occasions: Comparative Perspectives on Alcohol and Culture.
Heckman TG, Somlai AM, Peters J, Walker J, Otto-Salaj L, Galdabini CA, Kelly JA. (1998). Barriers to care among persons living with HIV/AIDS in urban and rural areas. AIDS Care.
Hemmingsson T, Lundberg I, Diderichsen F. (1999). The roles of social class of origin, achieved social class and intergenerational social mobility in explaining social-class inequalities in alcoholism among young men. Social Science and Medicine.
Hemmingsson T, Lundberg I, Diderichsen F, Allebeck P. (1998). Explanations of social class differences in alcoholism among young men. Social Science and Medicine.
Hendershot CS, George WH. (2007). Alcohol and sexuality research in the AIDS era: Trends in publication activity, target populations and research design. AIDS and Behavior.
Herbert JT, Hunt B, Dell G. (1994). Counseling gay men and lesbians with alcohol problems. Journal of Rehabilitation.
Herbst MD, Batki SL, Manfredi LB, Jones T. (1996). Treatment outcomes for methadone clients receiving lump-sum payments at initiation of disability benefits. Psychiatric Services.
Herek GM. (2002). Thinking about AIDS and stigma: A psychologist's perspective. Journal of Law and Medical Ethics.
Heron M, Hoyert DL, Murphy SLXJ, Kochanik KD, Tejada-Vera B. (2009). Deaths: Pinal data for 2006. National Vital Statistics Reports.
Higgins ST, Budney AJ, Bickel WK, Badger GJ. (1994). Participation of significant others in outpatient behavioral treatment predicts greater cocaine abstinence. American Journal of Drug and Alcohol Abuse.
Higuchi S, Parrish KM, Dufour MC, Towle LH, Harford TC. (1994). Relationship between age and drinking patterns and drinking problems among Japanese, Japanese Americans, and Caucasians. Alcoholism: Clinical and Experimental Research.
Hiller ML, Knight K, Simpson DD. (1999). Prison-based substance abuse treatment, residential aftercare and recidivism. Addiction.
Hilton ME. (1991). Demographic distribution of drinking problems in 1984. Clark WB, Hilton ME, editors. Alcohol in America: Drinking Practices and Problems.
Hodgins DC, el Guebaly N, Addington J. (1997). Treatment of substance abusers: Single or mixed gender programs?. Addiction.
Hoffman F. (1994). Cultural adaptations of Alcoholics Anonymous to serve Hispanic populations. International Journal of Addictions.
Hoffman JA, Mayo DW, Koman JJ, Caudill BD. (1994). Description and initial use of the cocaine and sexuality questionnaire. Sexual Addiction & Compulsivity.
Hoge CW, Auchterlonie JL, Milliken CS. (2006). Mental health problems, use of mental health services, and attrition from military service after returning from deployment to Iraq or Afghanistan. Journal of the American Medical Association.
Hoge CW, Castro CA, Messer SC, McGurk D, Cotting DI, Koffman RL. (2004). Combat duty in Iraq and Afghanistan: Mental health problems and barriers to care. New England Journal of Medicine.
Hohman MM, Galt DH. (2001). Latinas in treatment: Comparisons of residents in a culturally specific recovery home with residents in non-specific recovery homes. Journal of Ethnic & Cultural Diversity in Social Work.
Holahan CJ, Moos RH, Holahan CK, Cronkite RC, Randall PK. (2001). Drinking to cope, emotional distress and alcohol use and abuse: A ten-year model. Journal of Studies on Alcohol.
Holmes WC, Slap GB. (1998). Sexual abuse of boys: Definition, prevalence, correlates, sequelae, and management. Journal of American Medical Association.
Hser YI, Huang D, Teruya C, Anglin MD. (2003). Gender comparisons of drug abuse treatment outcomes and predictors. Drug and Alcohol Dependence.
Hughes TA, Wilson DJ, Beck AJ. (2001). Trends in State Parole, 1990–2000. Bureau of Justice Statistics Special Report.
Hughes TL, Eliason M. (2002). Substance use and abuse in lesbian, gay, bisexual and transgender populations. Journal of Primary Prevention.
Human Rights Watch. (2008). Targeting Blacks: Drug Law Enforcement and Race in the United States.
Humphreys K, Moos RH. (2007). Encouraging posttreatment self-help group involvement to reduce demand for continuing care services: Two-year clinical and utilization outcomes. Alcoholism: Clinical and Experimental Research.
Humphreys K, Wing S, McCarty D, Chappel J, Gallant L, Haberle B, Horvath AT, Kaskutas LA, Kirk T, Kivlahan D, Laudet A, McCrady BS, McLellan AT, Morgenstern J, Townsend M, Weiss R. (2004). Self-help organizations for alcohol and drug problems: Toward evidence-based practice and policy. Journal of Substance Abuse Treatment.
Hunt GP, MacKenzie K, Joe-Laidler K. (2005). Alcohol and masculinity: The case of ethnic youth gangs. Wilson TM, editor. Drinking Cultures: Alcohol and Identity.
Hunt K, Lewars H, Emslie C, Batty GD. (2007). Decreased risk of death from coronary heart disease amongst men with higher ‘femininity’ scores: a general population cohort study. International Journal of Epidemiology.
Imber-Black E. (2002). Family rituals—from research to the consulting room and back again: Comment on the special section. Journal of Family Psychology.
Institute of Medicine. (1990). Broadening the Base of Treatment for Alcohol Problems.
Isenhart C. (1993). Masculine gender role stress in an inpatient sample of alcohol abusers. Psychology of Addictive Behaviors.
Isenhart C. (2001). Treating substance abuse in men. Brooks GR, Good GE, editors. The New Handbook of Psychotherapy and Counseling With Men: A Comprehensive Guide to Settings, Problems, and Treatment Approaches.
Iverson A, Nikolaou V, Greenberg N, Unwin C, Hull L, Hotopf M, Dandeker C, Ross J, Wessely SC. (2005). What happens to British veterans when they leave the armed forces?. European Journal of Public Health.
Jacobson IG, Ryan MAK, Hooper TI, Smith TC, Amoroso PJ, Boyko EJ, Gackstetter GD, Wells TS, Bell NS. (2008). Alcohol use and alcohol-related problems before and after military combat deployment. Journal of the American Medical Association.
Jaffe PG, Lemon NKD, Poisson SE. (2003). Child Custody and Domestic Violence: A Call for Safety and Accountability.
Jakupcak M. (2003). Masculine gender role stress and men's fear of emotions as predictors of self-reported aggression and violence. Violence and Victims.
Jarrett NC, Bellamy CD, Adeyemi SA. (2007). Men's health help-seeking and implications for practice. American Journal of Health Studies.
Jeffries JM, Menghraj S, Hairston CF. (2001). Serving Incarcerated and Ex-Offender Fathers and Their Families: A Review of the Field.
Johnson AK, Cnaan RA. (1995). Social work practice with homeless persons: State of the art. Research on Social Work Practice.
Johnson JL, Leff M. (1999). Children of substance abusers: Overview of research findings. Pediatrics.
Johnson ME, Brems C, Mills ME, Fisher DG. (2007). Psychiatric symptomatology among individuals in alcohol detoxification treatment. Addictive Behaviors.
Johnson NG. (2001). Women helping men: Strengths of and barriers to women therapists working with men clients. Brooks GR, Good GE, editors. The New Handbook of Psychotherapy and Counseling With Men.
Johnson PB, Glassman M. (1998). The relationship between ethnicity, gender and alcohol consumption: A strategy for testing competing models. Addiction.
Johnson VE. (1986). Intervention: How To Help Someone Who Doesn't Want Help: A Step-by-Step Guide for Families and Friends of Chemically Dependent Persons.
Johnston LD, O'Malley PM, Bachman JG, Schulenberg JE. (2003). Monitoring the Future: National Survey Results on Drug Use, 1975–2003. Volume I: Secondary School Students.
Joint Commission on Accreditation of Healthcare Organizations. (2004). Spiritual Assessment.
Jones TR, Pratt TC. (2008). The prevalence of sexual violence in prison: The state of the knowledge base and implications for evidence-based correctional policymaking. International Journal of Offender Therapy and Comparative Criminology.
Jones-Webb RJ, Hsiao CY, Hannan P. (1995). Relationships between socioeconomic status and drinking problems among black and white men. Alcoholism: Clinical and Experimental Research.
Jonker J, De Jong CA, de Weert-van Oene GH, Gijs L. (2000). Gender-role stereotypes and interpersonal behavior: How addicted inpatients view their ideal male and female therapist. Journal of Substance Abuse Treatment.
Joyce PR, Sellman D, Wells E, Frampton CM. (1994). Parental bonding in men with alcohol disorders: A relationship with conduct disorder. Australian and New Zealand Journal of Psychiatry.
Kalichman SC, Johnson JR, Adair V, Rompa D, Multhauf K, Kelly JA. (1994). Sexual sensation seeking: Scale development and predicting AIDS-risk behavior among homosexually active men. Journal of Personality Assessment.
Kalichman SC, Rompa D. (1995). Sexual sensation seeking and sexual compulsivity scales: Reliability, validity, and predicting HIV risk behavior. Journal of Personality Assessment.
Kanayama G, Cohane GH, Weiss RD, Pope J. (2003). Past anabolic-androgenic steroid use among men admitted for substance abuse treatment: An underrecognized problem?. Journal of Clinical Psychiatry.
Kanayama G, Hudson JI, Pope HG. (2008). Long-term psychiatric and medical consequences of anabolic-androgenic steroid abuse: A looming public health concern?. Drug and Alcohol Dependence.
Kantor GK, Asdigian NL. (1997). Gender differences in alcohol-related spousal aggression. Wilsnack RW, Wilsnack SC, editors. Gender and Alcohol.
Karberg JC, James DJ. (2005). Substance Dependence, Abuse, and Treatment of Jail Inmates, 2002.
Karno MP, Longabaugh RL. (2004). What do we know? Process analysis and the search for a better understanding of Project MATCH's anger-by-treatment matching effect. Journal of Studies on Alcohol.
Kashner TM, Rosenheck R, Campinell AB, Suris A, Crandall R, Garfield NJ, Lapuc P, Pyrcz K, Soyka T, Wicker A. (2002). Impact of work therapy on health status among homeless, substance-dependent veterans: A randomized controlled trial. Archives of General Psychiatry.
Kasprow WJ, Rosenheck R, Frisman L, DiLella D. (1999). Residential treatment for dually diagnosed homeless veterans: A comparison of program types. American Journal on Addictions.
Kaufman J, Zigler E. (1993). The intergenerational transmission of violence is overstated. Gelles RJ, Loseke DR, editors. Current Controversies on Family Violence.
Kausch O. (2003). Patterns of substance abuse among treatment-seeking pathological gamblers. Journal of Substance Abuse Treatment.
Keen S. (1991). Fire in the Belly: On Being a Man.
Kelley ML, Fals-Stewart W. (2002). Couples- versus individual-based therapy for alcohol and drug abuse: Effects on children's psychosocial functioning. Journal of Consulting and Clinical Psychology.
Keltner D, Harker L. (1998). The forms and functions of the nonverbal signal of shame. Gilbert P, Andrews B, editors. Shame: Interpersonal Behavior, Psychopathology, and Culture.
Kessler RC. (1998). Sex differences in DSM-III-R psychiatric disorders in the United States: Results from the National Comorbidity Survey. Journal of the American Medical Women's Association.
Kessler RC. (2000). Gender and mood disorders. Goldman M, Hatch M, editors. Women and Health.
Kessler RC. (2000). Posttraumatic stress disorder: the burden to the individual and to society. Journal of Clinical Psychiatry.
Kessler RC. (2007). The global burden of anxiety and mood disorders: Putting the European Study of the Epidemiology of Mental Disorders (ESEMeD) findings into perspective. Journal of Clinical Psychiatry.
Kessler RC, Hwang I, LaBrie R, Petukhova M, Sampson NA, Winters KC, Shaffer HJ. (2008). DSM-IV pathological gambling in the National Comorbidity Survey replication. Psychological Medicine.
Kessler RC, McGonagle KA, Zhao S, Nelson CB, Hughes M, Eshleman S, Wittchen HU, Kendler KS. (1994). Lifetime and 12-month prevalence of DSM-III-R psychiatric disorders in the United States. Archives of General Psychiatry.
Kessler RC, Nelson CB, McGonagle KA, Edlund MJ, Frank RG, Leaf PJ. (1996). The epidemiology of co-occurring addictive and mental disorders: Implications for prevention and service utilization. American Journal of Orthopsychiatry.
Kessler RC, Nelson CB, McGonagle KA, Liu J, Swartz M, Blazer DG. (1996). Comorbidity of DSM-III-R major depressive disorder in the general population: Results from the U.S. National Comorbidity Survey. British Journal of Psychiatry.
Kessler RC, Sonnega A, Bromet E, Hughes M, Nelson CB. (1995). Posttraumatic stress disorder in the National Comorbidity. Survey Archives of General Psychiatry.
Kilmer B, Caulkins JP, Liccardo Pacula R, MacCoun RJ, Reuter PH. (2010). Altered State? Assessing How Marijuana Legalization in California Could Influence Marijuana Consumption and Public Budgets.
Kilts CD, Gross RE, Ely TD, Drexler KPG. (2004). The neural correlates of cue-induced craving in cocaine-dependent women. American Journal of Psychiatry.
Kimmel MS, Messner MA. (2010). Men's Lives.
King RS. (2008). Disparity by Geography: The War on Drugs in America's Cities.
Kirby KC, Lamb RJ, Iguchi MY, Husband SD, Platt JJ. (1995). Situations occasioning cocaine use and cocaine abstinence strategies. Addiction.
Kirisci L, Dunn MG, Mezzich AC, Tarter RE. (2001). Impact of parental substance use disorder and child neglect severity on substance use involvement in male offspring. Prevention Science.
Kiselica MS. (1996). Parenting skills training with teenage fathers. Andronico MP, editor. Men in Groups: Insights, Interventions, and Psychoeducational Work.
Klein H. (1990). Contemporary Italian American college student drinking patterns. Scelsa J, LaGumina S, Tomasi L, editors. Italian Americans in Transition.
Kline A. (1996). Pathways into drug user treatment: The influence of gender and racial/ethnic identity. Substance Use and Misuse.
Klitzman RL, Greenberg JD, Pollack LM, Dolezal C. (2002). MDMA (“ecstasy”) use, and its association with high risk behaviors, mental health, and other factors among gay/bisexual men in New York City. Drug and Alcohol Dependence.
Klonoff-Cohen H, Lam-Kruglick P, Gonzalez C. (2003). Effects of maternal and parental alcohol consumption on the success rates of in vitro fertilization and gamete intrafallopian transfer. Fertility and Sterility.
Klonsky DE, Jane JS, Turkheimer E, Oltmanns TF. (2002). Gender role and personality disorders. Journal of Personality Disorders.
Knupfer G. (1989). The prevalence in various social groups of eight different drinking patterns, from abstaining to frequent drunkenness: Analysis of 10 U.S. surveys combined. British Journal of Addiction.
Koenen KC, Lyons MJ, Goldberg J, Simpson JC, Williams WM, Toomey R, Eisen SA, True WR, Cloitre M, Wolfe J, Tsuang MT. (2003). A high risk twin study of combat-related PTSD comorbidity. Twin Research.
Koenig HG. (2001). Religion and medicine II: Religion, mental health, and related behaviors. International Journal of Psychiatry in Medicine.
Koenig HG. (2001). Religion and medicine IV: Religion, physical health, and clinical implications. International Journal of Psychiatry in Medicine.
Kohn CS, Mertens JR, Weisner CM. (2002). Coping among individuals seeking private chemical dependence treatment: Gender differences and impact on length of stay in treatment. Alcoholism: Clinical and Experimental Research.
Koss MP, Dinero TE. (1988). Predictors of sexual aggression among a national sample of male college students. Annals of the New York Academy of Science.
Kraybill K, Zerger S. (2003). Providing Treatment for Homeless People With Substance Use Disorders: Case Studies of Six Programs.
(2000). Krestan J, editor. Bridges to Recovery: Addiction, Family Therapy, and Multicultural Treatment.
Kropp PR, Hart SD, Webster CD, Eaves D. (1995). Manual for the Spousal Assault Risk Assessment Guide.
Krugman S. (1995). Male development and the transformation of shame. Levant RF, Pollack WS, editors. A New Psychology of Men.
Krugman S. (1998). Men's shame and trauma in therapy. Pollack WS, Levant RF, editors. New Psychotherapy for Men.
Kulka RA, Schlenger WE, Fairbank JA, Hough RL, Jordan BK, Marmar CR, Weiss DS, Grady DA. (1990). Trauma and the Vietnam War Generation: Report of Findings From the National Vietnam Veterans Readjustment Study.
Kuntsche S, Knibbe RA, Gmel G. (2009). Social roles and alcohol consumption: A study of 10 industrialised countries. Social Science and Medicine.
Kunz JL, Graham K. (1996). Life course changes in alcohol consumption in leisure activities of men and women. Journal of Drug Issues.
Lab DD, Feigenbaum JD, De Silva P. (2000). Mental health professionals' attitudes and practices towards male childhood sexual abuse. Child Abuse & Neglect.
Ladd GT, Petry NM. (2003). A comparison of pathological gamblers with and without substance abuse treatment histories. Experimental and Clinical Psychopharmacology.
Ladd GT, Petry NM. (2002). Gender differences among pathological gamblers seeking treatment. Experimental and Clinical Psychopharmacology.
LairRobinson R. (1997). Men and gambling. Straussner SLA, Zelvin E, editors. Gender and Addictions: Men and Women in Treatment.
Landau J, Garrett J, Shea RR, Stanton MD, Brinkman-Sull D, Baciewicz G. (2000). Strength in numbers: The ARISE method for mobilizing family and network to engage substance abusers in treatment. A relational intervention sequence for engagement. American Journal of Drug and Alcohol Abuse.
Laudet AB, Morgen K, White WL. (2006). The role of social supports, spirituality, religiousness, life meaning and affiliation with 12-Step fellowships in quality of life satisfaction among individuals in recovery from alcohol and drug problems. Alcohol Treatment Quarterly.
Lazare A. (1997). Shame, humiliation, and stigma in the medical interview. Lansky MR, Morrison AP, editors. The Widening Scope of Shame.
Lazarus RS, Folkman S. (1984). Stress, Appraisal, and Coping.
Lazur RF. (1998). Men in the family: A family system's approach to treating men. Pollack WS, Levant RF, editors. New Psychotherapy for Men.
Lebow J, Kelly JF, Knobloch-Fedders LM, Moos R. (2005). Relationship factors in treating substance use disorders. Castonguay LG, Beutler LE, editors. Principles of Therapeutic Change That Work.
Lee AJ, Crombie IK, Smith WC, Tunstall-Pedoe H. (1990). Alcohol consumption and unemployment among men: The Scottish Heart Health Study. British Journal of Addiction.
Lee LC, Zane N. (1998). Addictive behaviors. Lee LC, Zane NWS, editors. Handbook of Asian American Psychology.
Lehman WE, Bennett JB. (2002). Job risk and employee substance use: The influence of personal background and work environment factors. American Journal of Drug and Alcohol Abuse.
Lejuez CW, Simmons BL, Aklin WM, Daughters SB, Dvir S. (2004). Risk-taking propensity and risky sexual behavior of individuals in residential substance use treatment. Addictive Behaviors.
Lemke S, Schutte KK, Brennan PL, Moos RH. (2008). Gender differences in social influences and stressors linked to increased drinking. Journal of Studies on Alcohol and Drugs.
Lesser J, Tello J, Koniak-Griffin D, Kappos B, Rhys M. (2001). Young Latino fathers' perceptions of paternal role and risk for HIV/AIDS. Hispanic Journal of Behavioral Sciences.
Levant RF. (1995). Toward the reconstruction of masculinity. Levant RF, Pollack WS, editors. A New Psychology of Men.
Levant RF. (1996). The male code and parenting: A psychoeducational approach. Andronico MP, editor. Men in Groups: Insights, Interventions, and Psychoeducational Work.
Levant RF, Hall RJ, Williams C, Hasan NT. (2009). Gender differences in alexithymia: A meta-analysis. Psychology of Men & Masculinity.
Levant RF, Hirsch LS, Celentano E, Cozza TM, Hill S, MacEachern M, Marty N, Schnedeker J. (1992). The male role: An investigation of contemporary norms. Journal of Mental Health Counseling.
Levant RF, Majors RG, Kelley ML. (1998). Masculinity ideology among young African American and European American women and men in different regions of the United States. Cultural Diversity and Mental Health.
Levant RF, Philpot CL. (2002). Conceptualizing gender in marital and family therapy research: The gender role strain paradigm. Liddle HA, Santisteban DA, Levant RF, Bray JH, editors. Family Psychology: Science-Based Interventions.
(1995). Levant RF, Pollack WS, editors. A New Psychology of Men.
Levant RF, Silverstein LB. (2001). Integrating gender and family systems theories: The “both/and” approach to treating a postmodern couple. McDaniel SH, Lusterman DD, Philpot CL, editors. Casebook for Integrating Family Therapy: An Ecosystemic Approach.
Levin Y, Sanacora G. (2007). Depression. Grant J.E, Potenza M.N, editors. Textbook of Mens Mental Health.
Lewis HB. (1971). Shame and Guilt in Neurosis.
Lex BW. (2000). Gender and cultural influences on substance abuse. Eisler RM, Hersen M, editors. Handbook of Gender, Culture, and Health.
Li J, Liu H, Liu H, Feng T, Cai Y. (2011). Psychometric assessment of HIV/STI sexual risk scale among MSM: A Rasch model approach. BMC Public Health.
Lichtenstein B. (2009). Drugs, incarceration, and HIV/AIDS among African American men: A critical literature review and call to action. American Journal of Men's Health.
Link BG, Struening EL, Rahav M, Phelan JC, Nuttbrock L. (1997). On stigma and its consequences: Evidence from a longitudinal study on men and dual diagnosis of mental illness and substance abuse. Journal of Health and Social Behavior.
Lisak D. (2001). Homicide, violence, and male aggression. Brooks G.R, Good GE, editors. The New Handbook of Psychotherapy and Counseling With Men: A Comprehensive Guide to Settings, Problems, and Treatment Approaches.
Lisak D. (2001). Male survivors of trauma. Brooks G.R, Good GE, editors. The New Handbook of Psychotherapy and Counseling With Men: A Comprehensive Guide to Settings, Problems, and Treatment Approaches.
Liu WM. (2002). The social class-related experiences of men: Integrating theory and practice. Professional Psychology: Research and Practice.
Liu WM. (2005). The study of men and masculinity as an important multicultural competency consideration. Journal of Clinical Psychology.
Liu WM, Iwamoto DK. (2006). Asian American men's gender role conflict: The role of Asian values, self-esteem, and psychological distress. Psychology of Men & Masculinity.
Liu WM, Rochlen A, Mohr JJ. (2005). Real and ideal gender-role conflict: Exploring psychological distress among men. Psychology of Men & Masculinity.
Lo CC, Stephens RC. (2002). Arrestees' perceived needs for substance-specific treatment: Exploring urban-rural differences. American Journal of Drug and Alcohol Abuse.
Loneck B, Garrett JA, Banks SM. (1996). A comparison of the Johnson intervention with four other methods of referral to outpatient treatment. American Journal of Drug and Alcohol Abuse.
Lopez AD. (2004). The Global Burden of Disease: 2020 Focus 5.
Luczak SE, Elvine-Kreis B, Shea SH, Carr LG, Wall T.L. (2002). Genetic risk for alcoholism relates to level of response to alcohol in Asian American men and women. Journal of Studies on Alcohol.
Luthar SS, Suchman NE. (1999). Developmentally informed parenting interventions: The relational psychotherapy mothers' group. Cicchetti D, Toth SL, editors. Rochester Symposium on Developmental Psychopathology: Developmental Approaches to Prevention and Intervention.
Luthar SS, Suchman NE. (2000). Relational psychotherapy mothers' group: A developmentally informed intervention for at-risk mothers. Development and Psychopathology.
Lyme A, Powell DJ, Andrew S. (2008). Men's Healing: Toolbox for Life.
Lyons M. (1991). Enabling or disabling? Students' attitudes toward persons with disabilities. American Journal of Occupational Therapy.
Ma GX, Shive S, Tan Y, Toubbeh J. (2002). Prevalence and predictors of tobacco use among Asian Americans in the Delaware Valley region. American Journal of Public Health.
MacDonald J. (1998). Disclosing shame. Gilbert P, Andrews B, editors. Shame: Interpersonal Behavior, Psychopathology, and Culture.
Magovcevic M, Addis ME. (2005). Linking gender-role conflict to nonnormative and self stigmatizing perceptions of alcohol abuse and depression. Psychology of Men & Masculinity.
Mahalik JR, Good GE, Englar-Carlson M. (2003). Masculinity scripts, presenting concerns, and help seeking: Implications for practice and training. Professional Psychology: Research and Practice.
Mahalik JR, Locke BD, Ludlow LH, Diemer MA, Scott RPJ, Gottfried M, Freitas G. (2003). Development of the conformity to masculine norms inventory. Psychology of Men and Masculinity.
Mahalik JR, Talmadge WT, Locke BD, Scott RP. (2005). Using the conformity to masculine norms inventory to work with men in a clinical setting. Journal of Clinical Psychology.
Makino M, Tsuboi K, Dennerstein L. (2004). Prevalence of eating disorders: A comparison of Western and non-Western countries. Medscape General Medicine.
Mancebo MC, Grant JE, Pinto A, Eisen JL, Rasmussen SA. (2009). Substance use disorders in an obsessive compulsive disorder clinical sample. Journal of Anxiety Disorders.
Mannelli P, Pae CU. (2007). Medical comorbidity and alcohol dependence. Current Psychiatry Reports.
Mansfield AK, Addis ME, Courtenay W. (2005). Measurement of men's help seeking: Development and evaluation of the barriers to help-seeking scale. Psychology of Men & Masculinity.
Marini ID. (2001). Issues of males with physical disabilities in rehabilitation settings. Brooks G.R, Good GE, editors. The New Handbook of Psychotherapy and Counseling With Men: A Comprehensive Guide to Settings, Problems, and Treatment Approaches.
Marlatt GA. (1985). Relapse prevention: Theoretical rationale and overview of the model. Marlatt GA, Gordon JR, editors. Relapse Prevention: Maintenance Strategies in the Treatment of Addictive Behaviors.
Marlatt GA. (1996). Taxonomy of high-risk situations for alcohol relapse: Evolution and development of a cognitive-behavioral model. Addiction.
Marlin E. (1989). Genograms: The New Tool for Exploring the Personality, Career, and Love Patterns You Inherit.
Marsella AJ. (1998). Urbanization, mental health, and social deviancy: A review of issues and research. American Psychologist.
Marsh JC, Cao D. (2004). and D'Aunno, T Gender differences in the impact of comprehensive services in substance abuse treatment. Journal of Substance Abuse Treatment.
Martens MP, Dams-O'Connor K, Beck N.C. (2006). A systematic review of college student-athlete drinking: Prevalence rates, sport-related factors, and interventions. Journal of Substance Abuse Treatment.
Massoglia M. (2008). Incarceration, health, and racial disparities in health. Law & Society Review.
Masten AS, Faden VB, Zucker RA, Spear LP. (2008). Underage drinking: A developmental framework. Pediatrics.
Mathews F. (1996). The Invisible Boy: Revisioning the Victimization of Male Children and Teens.
May PA, Gossage P. (2001). New data on the epidemiology of adult drinking and substance use among American Indians of the Northern States: Male and female data on prevalence, patterns, and consequences. American Indian and Alaska Native Mental Health Research.
Maynard C, Cox GB, Krupski A, Stark K. (1999). Utilization of services for mentally ill chemically abusing patients discharged from residential treatment. The Journal of Behavioral Health Services and Research.
McCabe SE, Hughes TL, Bostwick WB, West BT, Boyd CJ. (2009). Sexual orientation, substance use behaviors and substance dependence in the United States. Addiction.
McCaul ME, Svikis DS, Moore RD. (2001). Predictors of outpatient treatment retention: Patient versus substance use characteristics. Drug and Alcohol Dependence.
McClelland DC, Davis WN, Kalin R, Wanner E. (1972). The Drinking Man: Alcohol and Human Motivation.
McCormick RA, Smith M. (1995). Aggression and hostility in substance abusers: The relationship to abuse patterns, coping style, and relapse triggers. Addictive Behaviors.
McCrady BS, Epstein EE, Kahler CW. (2004). Alcoholics Anonymous and relapse prevention as maintenance strategies after conjoint behavioral alcohol treatment for men: 18-month outcomes. Journal of Consulting and Clinical Psychology.
McCurdy K, Daro D. (1994). Current Trends in Child Abuse Reporting and Fatalities: The Results of the 1993 Annual Fifty State Survey.
McElroy SL, Soutullo CA, Taylor P, Nelson E.B, Beckman DA, Brusman LA, Ombaba JM, Strakowski SM, Keck PE. (1999). Psychiatric features of 36 men convicted of sexual offenses. Journal of Clinical Psychiatry.
McFall ME, Fontana A, Raskind MA, Rosenheck RA. (1999). Analysis of violent behavior in Vietnam combat veteran psychiatric inpatients with posttraumatic stress disorder. Journal of Traumatic Stress.
McGoldrick M. (1995). You Can Go Home Again: Reconnecting With Your Family.
(1998). McGoldrick M, editor. Re-Visioning Family Therapy: Race, Culture, and Gender in Clinical Practice.
McGoldrick M, Gerson R, Petry SS. (2008). Genograms: Assessment and Intervention.
(2005). McGoldrick M, Giordano J, Garcia-Preto N, editors. Ethnicity and Family Therapy.
McKay JR, Lynch KG, Shepard DS, Morgenstern J, Forman RF, Pettinati HM. (2005). Do patient characteristics and initial progress in treatment moderate the effectiveness of telephone-based continuing care for substance use disorders?. Addiction.
McKay JR, Rutherford MJ, Alterman AI, Cacciola JS, Kaplan MR. (1995). An examination of the cocaine relapse process. Drug and Alcohol Dependence.
McKay JR, Rutherford MJ, Cacciola JS, Kabasakalian-McKay R, Alterman AI. (1996). Gender differences in the relapse experiences of cocaine patients. Journal of Nervous and Mental Disease.
McKinnon J. (2001). The Black Population: 2000.
McKinnon J. (2003). The Black Population in the United States: 2002: Current Population Reports.
McLellan AT, Hagan TA, Levine M, Meyers K, Gould R, Bencivengo M, Durell J, Jaffe J. (1999). Does clinical case management improve outpatient addiction treatment?. Drug and Alcohol Dependence.
McLellan AT, Lewis DC, O'Brien CR, Kleber HD. (2000). Drug dependence, a chronic medical illness: Implications for treatment, insurance, and outcomes evaluation. Journal of the American Medical Association.
McMahon TJ. (2003). Drug dependence, psychological representations of fathering, and reproductive strategy. Dewey WL, Harris LS, editors. Problems of Drug Dependence, 2002.
McMahon TJ, Giannini FD. (2002). Fathers Too! A Psychosocial Intervention for Drug-Abusing Fathers.
McMahon TJ, Giannini FD. (2003). Substance-abusing fathers in family court: Moving from popular stereotypes to therapeutic jurisprudence. Family Court Review.
McMahon TJ, Rounsaville BJ. (2002). Substance abuse and fathering: Adding poppa to the research agenda. Addiction.
McMahon TJ, Winkel JD, Luthar SS, Rounsaville BJ. (2005). Looking for poppa: Parenting status of men versus women seeking drug abuse treatment. American Journal of Drug and Alcohol Abuse.
McMillin S. (1995). A warning from SOAR: Stigma kills. Addiction Letter.
McNeely RL, Cook PW, Torres JB. (2001). Is domestic violence a gender issue, or a human issue?. See LAL, editor. Violence as Seen Through a Prism of Color.
McRae AL, Hedden SL, Malcolm RJ, Carter RE, Brady KT. (2007). Characteristics of cocaine- and marijuana-dependent subjects presenting for medication treatment trials. Addictive Behaviors.
Menninger JA. (2002). Assessment and treatment of alcoholism and substance-related disorders in the elderly. Bulletin of the Menninger Clinic.
Mensinger J.L, Lynch KG, TenHave TR, McKay JR. (2007). Mediators of telephone-based continuing care for alcohol and cocaine dependence. Journal of Consulting and Clinical Psychology.
Mertens JR, Weisner CM. (2000). Predictors of substance abuse treatment retention among women and men in an HMO. Alcoholism: Clinical and Experimental Research.
Messina N, Burdon W, Hagopian G, Prendergast M. (2006). Predictors of prison-based treatment outcomes: A comparison of men and women participants. American Journal of Drug and Alcohol Abuse.
Messina N, Wish E, Nemes S. (2000). Predictors of treatment outcomes in men and women admitted to a therapeutic community. American Journal of Drug and Alcohol Abuse.
Meyer IH. (1995). Minority stress and mental health in gay men. Journal of Health and Social Behavior.
Meyers RJ, Dominguez TP, Smith JE. (1996). Community reinforcement training with concerned others. Van Hasselt VB, Hersen M, editors. Sourcebook of Psychological Treatment Manuals for Adult Disorders.
Meyers RJ, Miller WR, Smith JE. (2001). Community reinforcement and family training (CRAFT). Meyers RJ, Miller WR, editors. A Community Reinforcement Approach to Addiction Treatment.
Miller BA. (1996). Women's alcohol use and their violent victimization. Howard JM, Martin SE, Mail PD, Hilton ME, Taylor ED, editors. Women and Alcohol: Issues for Prevention Research.
Miller BA, Downs WR, Gondoli DM. (1989). Spousal violence among alcoholic women as compared to a random household sample of women. Journal of Studies on Alcoholism.
Miller JB. (1984). The Development of Women's Sense of Self.
Miller NS. (1997). Generalized vulnerability to drug and alcohol addiction. Miller NS, editor. Principles and Practice of Addictions in Psychiatry.
Miller NS, Flaherty JA. (2000). Effectiveness of coerced addiction treatment (alternative consequences): A review of the clinical research. Journal of Substance Abuse Treatment.
Miller WR, Andrews NR, Wilbourne P, Bennett ME. (1998). A wealth of alternatives: Effective treatments for alcohol problems. Miller WR, Heather N, editors. Treating Addictive Behaviors: Processes of Change.
Miller WR, Benefield RG, Tonigan JS. (1993). Enhancing motivation for change in problem drinking: A controlled comparison of two therapist styles. Journal of Consulting and Clinical Psychology.
Miller WR, Meyers RJ, Tonigan JS. (1999). Engaging the unmotivated in treatment for alcohol problems: A comparison of three strategies for intervention through family members. Journal of Consulting and Clinical Psychology.
Miller WR, Rollnick S. (2002). Motivational Interviewing: Preparing People for Change.
Miller WR, Thoresen CE. (1999). Spirituality and health. Miller WR, editor. Integrating Spirituality Into Treatment: Resources for Practitioners.
Miller WR, Westerberg VS, Harris RJ, Tonigan JS. (1996). What predicts relapse? Prospective testing of antecedent models. Addiction.
Millery MP, Kleinman BP. Gender Differences in Psychiatric Profiles in a Detoxification Sample of Drug Abusers: Antisocial Men and Traumatized Women. Poster presented at the College for Problems in Drug Dependence (June).
Minino AM, Arias E, Kochanek KD, Murphy SL, Smith BL. (2002). Deaths: Final Data for 2000.
Monk D, Ricciardelli LA. (2003). Three dimensions of the male gender role as correlates of alcohol and cannabis involvement in young Australian men. Psychology of Men & Masculinity.
Moos RH. (2008). Active ingredients of substance use-focused self-help groups. Addiction.
Moos RH, Moos BS. (2006). Participation in treatment and Alcoholics Anonymous: A 16-year follow-up of initially untreated individuals. Journal of Clinical Psychology.
Moos RH, Moos BS, Timko C. (2006). Gender, treatment and self-help in remission from alcohol use disorders. Clinical Medicine Research.
Moriarty PJ, Lieber D, Bennett A, White L, Parrella M, Harvey PD, Davis KL. (2001). Gender differences in poor outcome patients with lifelong schizophrenia. Schizophrenia Bulletin.
Moss HB, Mezzich A, Yao JK, Gavaler J, Martin CS. (1995). Aggressivity among sons of substance-abusing fathers: Association with psychiatric disorder in the father and son, paternal personality, pubertal development, and socioeconomic status. American Journal of Drug and Alcohol Abuse.
Moss HB, Vanyukov M, Majumder PP, Kirisci L, Tarter RE. (1995). Prepubertal sons of substance abusers: Influences of parental and familial substance abuse on behavioral disposition, IQ, and school achievement. Addictive Behaviors.
Muehlenhard CL, Linton MA. (1987). Date rape and sexual aggression in dating situations: Incidence and risk factors. Journal of Counseling Psychology.
Müller S, Piontek D, Pabst A, Baumeister SE, Kraus L. (2010). Changes in alcohol consumption and beverage preference among adolescents after the introduction of the alcopops tax in Germany. Addiction.
Mulvey KP, Hubbard S, Hayashi S. (2003). A national study of the substance abuse treatment workforce. Journal of Substance Abuse Treatment.
Nadler A, Maler S, Friedman A. (1984). Effects of helper's sex, subjects' androgyny, and self-evaluation on males' and females' willingness to seek and receive help. Sex Roles.
Najavits LM, Schmitz M, Gotthardt S, Weiss RD. (2005). Seeking safety plus exposure therapy: An outcome study on dual diagnosis men. Journal of Psychoactive Drugs.
Nasser EH, Walders N, Jenkins JH. (2002). The experience of schizophrenia: What's gender got to do with it? A critical review of the current status of research on schizophrenia. Schizophrenia Bulletin.
National Center for Health Statistics. (2007). Table 27. Life Expectancy at Birth, at 65 Years of Age, and at 75 Years of Age, by Race and Sex: United States, Selected Years 1900-2005.
National Center for PTSD and Walter Reed Army Medical Center. (2004). Iraq War Clinician Guide.
National Institute for Occupational Safety and Health. (2004). Worker Health Chartbook, 2004.
National Institute of Justice. (2003). 2000 Arrestee Drug Abuse Monitoring: Annual Report.
National Institute of Mental Health. (2001). In Harm's Way: Suicide in America.
National Institute of Mental Health. (2003). Men and Depression.
National Institute on Alcohol Abuse and Alcoholism. (1999). Alcohol and the Workplace.
National Institute on Alcohol Abuse and Alcoholism. (1995). The Physicians' Guide to Helping Patients With Alcohol Problems.
National Institute on Alcohol Abuse and Alcoholism. (2002). Screening for Alcohol Problems: An Update.
National Institute on Alcohol Abuse and Alcoholism. (2005). Module 10C: Older Adults and Alcohol Problems.
National Institute on Drug Abuse. (1994). Assessing Drug Abuse Among Adolescents and Adults: Standardized Instruments.
National Institute on Drug Abuse. (1996). Visual technique helps drug abuse treatment patients map road to recovery. NIDA Notes.
National Institute on Drug Abuse. (1998). NIDA Community Drug Alert Bulletin: Methamphetamine.
National Institute on Drug Abuse. (1999). Drug Abuse and Addiction Research: 25 Years of Discovery to Advance the Health of the Public: The Sixth Triennial Report to Congress From the Secretary of Health and Human Services.
National Institute on Drug Abuse. (2000). Anabolic Steroid Abuse.
National Institute on Drug Abuse. (2003). Group Therapy Research.
Neff JA, Prihoda TJ, Hoppe SK. (1991). “Machismo,” self-esteem, education and high maximum drinking among Anglo, Black and Mexican American male drinkers. Journal of Studies on Alcohol.
Nemoto T, Aoki B, Huang K, Morris A, Nguyen H, Wong W. (1999). Drug use behaviors among Asian drug users in San Francisco. Addictive Behaviors.
Nemoto T, Operario D, Soma T. (2002). Risk behaviors of Filipino methamphetamine users in San Francisco: Implications for prevention and treatment of drug use and HIV. Public Health Reports.
Nesic J, Duka T. (2006). Gender specific effects of a mild stressor on alcohol cue reactivity in heavy social drinkers. Pharmacology, Biochemistry and Behavior.
Neve RJ, Lemmens PH, Drop MJ. (1999). Older and younger male alcoholics in outpatient treatment. Addictive Behaviors.
Nielsen AL. (2000). Examining drinking patterns and problems among Hispanic groups: Results from a national. survey Journal of Studies on Alcohol.
Niv N, Hser YI. (2007). Women-only and mixed-gender drug abuse treatment programs: Service needs, utilization and outcomes. Drug and Alcohol Dependence.
Niv N, Wong EC, Hser YI. (2007). Asian Americans in community-based substance abuse treatment: Service needs, utilization, and outcomes. Journal of Substance Abuse Treatment.
Nock MK, Kessler RC. (2006). Prevalence of and risk factors for suicide attempts versus suicide gestures: Analysis of the National Comorbidity Survey. Journal of Abnormal Psychology.
Nonn T. (2007). Hitting bottom: Homelessness, poverty, and masculinity. Arrighi B, editor. Understanding Inequality: The Intersection of Race/Ethnicity, Class, and Gender.
North CS, Eyrich KM, Pollio DE, Spitznagel EL. (2004). Are rates of psychiatric disorders in the homeless population changing?. American Journal of Public Health.
Nudell DM, Monoski MM, Lipschultz LI. (2002). Common medications and drugs: How they affect male fertility. Urologic Clinics of North America.
Nye CL, Zucker RA, Fitzgerald HE. (1995). Early intervention in the path to alcohol problems through conduct problems: Treatment involvement and child behavior change. Journal of Consulting and Clinical Psychology.
O'Dwyer P. (2001). The Irish and substance abuse. Straussner SLA, editor. EthnoculturalFactors in Substance Abuse Treatment.
O'FarrelL T.J, Choquette K.A, Cutter H.S. (1998). Couples relapse prevention sessions after behavioral marital therapy for male alcoholics: Outcomes during the three years after starting treatment. Journal of 'Studies on Alcohol.
O'Farrell T.J, Fals-Stewart W. (1999). Treatment models and methods: Family models. McCrady BS, Epstein EE, editors. Addictions: A Comprehensive Guidebook.
O'Farrell TJ, Fals-Stewart W, Murphy CM, Stephan SH, Murphy M. (2004). Partner violence before and after couples-based alcoholism treatment for male alcoholic patients: The role of treatment involvement and abstinence. Journal of Consulting and Clinical Psychology.
Office of Applied Studies. (2001). How Men and Women Enter Substance Abuse Treatment.
Office of Applied Studies. (2002). Substance Use, Dependence or Abuse Among Full-Time Workers.
Office of Applied Studies. (2003). Veterans in Substance Abuse Treatment: 1995–2000.
Office of Applied Studies. (2004). Admissions With Co-Occurring Disorders: 1995 and 2001.
Office of Applied Studies. (2004). 2003 National Survey on Drug Use and Health: Detailed tables. Results From the 2003 National Survey on Drug Use and Health: National Findings.
Office of Applied Studies. (2005). Alcohol Use and Alcohol-Related Risk Behaviors Among Veterans.
Office of Applied Studies. (2007). Facilities Offering Special Treatment Programs or Groups: 2005.
Office of Applied Studies. (2007). Substance Use and Substance Use Disorders Among American Indians and Alaska Natives.
Oggins J, Guydish J, Delucchi K. (2001). Gender differences in income after substance abuse treatment. Journal of Substance Abuse Treatment.
Ogunwole SU. (2006). We the People: American Indians and Alaska Natives in the United States.
Ohannessian CM, Hesselbrock VM. (1993). The influence of perceived social support on the relationship between family history of alcoholism and drinking behaviors. Addiction.
Ojeda L, Rosales R, Good GE. (2008). Socioeconomic status and cultural predictors of male role attitudes among Mexican American men: ¿ Son Más Machos?. Psychology of Men & Masculinity.
O'Neil JM, Good GE, Holmes S. (1995). Fifteen years of theory and research on men's gender role conflict: New paradigms for empirical research. Levant RF, Pollack WS, editors. A New Psychology of Men.
O'Neil J.M, Helms B.J, Gable R.K, David L, Wrightsman L.S. (1986). Gender-role conflict scale: College men's fear of femininity. Sex Roles.
Operario D, Smith CD, Arnold E, Kegeles S. (2009). Sexual risk and substance use behaviors among African American men who have sex with men and women. AIDS and Behavior.
Orloff E. (2001). Can marriage survive addiction?. Counselor.
Orwin RG, Francisco L, Bernichon T. (2001). Effectiveness of Women's Substance Abuse Treatment Programs: A Meta-Analysis.
Ouimette PC, Ahrens C, Moos R.H, Finney J.W. (1998). During treatment changes in substance abuse patients with posttraumatic stress disorder: The influence of specific interventions and program environments. Journal of Substance Abuse Treatment.
Ouimette PC, Kimerling R, Shaw J, Moos RH. (2000). Physical and sexual abuse among women and men with substance use disorders. Alcoholism Treatment Quarterly.
Overholser JC, Freiheit SR, DiFilippo J.M. (1997). Emotional distress and substance abuse as risk factors for suicide attempts. Canadian Journal of Psychiatry.
Padilla AM, Salgado de Snyder V.N. (1992). Hispanics: What the culturally informed evaluator needs to know. Orlandi MA, Weston R, Epstein LG, editors. Cultural Competence for Evaluators: A Guide for Alcohol and Other Drug Abuse Prevention Practitioners Working With Ethnic/Racial Communities.
Page RC, Berkow DN. (1998). Group work as facilitation of spiritual development for drug and alcohol abusers. Journal for Specialists in Group Work.
Paris J. (2004). Gender differences in personality traits and disorders. Current Psychiatry Reports.
Park MJ, Mulye TP, Adams SH, Brindis CD, Irwin J. (2006). The health status of young adults in the United States. Journal of Adolescent Health.
Parke RD, Brott AA. (1999). Throwaway Dads: The Myths and Barriers That Keep Men From Being the Fathers They Want To Be.
Parrott DJ, Giancola PR. (2004). A further examination of the relation between trait anger and alcohol-related aggression: The role of anger control. Alcoholism: Clinical and Experimental Research.
Parrott DJ, Zeichner A. (2002). Effects of alcohol and trait anger on physical aggression in men. Journal of Studies on Alcohol.
Pederson EL, Vogel DL. (2007). Male gender role conflict and willingness to seek counseling: Testing a mediation model on college-aged men. Journal of Counseling Psychology.
Peralta R. (2007). College alcohol use and the embodiment of hegemonic masculinity among European American men. Sex Roles.
Perron BE, Mowbray OP, Glass JE, Delva J, Vaughn MG, Howard MO. (2009). Differences in service utilization and barriers among Blacks, Hispanics, and Whites with drug use disorders. Substance Abuse Treatment, Prevention, and Policy.
Peters MA, Phelps L. (2001). Body image dissatisfaction and distortion, steroid use, and sex differences in college age bodybuilders. Psychology in the Schools.
Peterson ZD, Janssen E, Heiman JR. (2009). The association between sexual aggression and HIV risk behavior in heterosexual men. Journal of Interpersonal Violence.
Petry NM, Bohn MJ. (2003). Fishbowls and candy bars: Using low-cost incentives to increase treatment retention. NIDA Science & Practice Perspectives.
Peugh J, Belenko S. (2001). Examining the substance abuse patterns and treatment needs of incarcerated sex offenders. Sexual Abuse: A Journal of Research and Treatment.
Philpot CL. (2001). Family therapy for men. Brooks G.R, Good GE, editors. The New Handbook of Psychotherapy and Counseling With Men: A Comprehensive Guide to Settings, Problems, and Treatment Approaches.
Philpot CL, Brooks GR. (1995). Intergender communication and gender-sensitive family therapy. Mikesell RH, Lusterman DD, McDaniel S, editors. Integrating Family Therapy: Handbook of Family Psychology and Systems Theory.
Philpot CL, Brooks GR, Lusterman DD, Nutt RL. (1997). Bridging Separate Gender Worlds: Why Men and Women Clash and How Therapists Can Bring Them Together.
Pinto A, Mancebo MC, Eisen JL, Pagano ME, Rasmussen SA. (2006). The Brown Longitudinal Obsessive Compulsive Study: Clinical features and symptoms of the sample at intake. Journal of Clinical Psychiatry.
Platt JJ. (1995). Vocational rehabilitation of drug abus. Psychological Bulletin.
Pleck JH. (1981). The Myth of Masculinity.
Pleck JH. (1995). The gender role strain paradigm: An update. Levant RF, Pollack WS, editors. A New Psychology of Men.
Pollack WS. (1994). Engendered psychotherapy: Listening to the male and female voice. Voices: The Art and Source of Psychotherapy.
Pollack WS. (1995). Deconstructing dis-identification: Rethinking psychoanalytic concepts of male development. Psychoanalysis & Psychotherapy.
Pollack WS. (1998). Mourning, melancholia, and masculinity. Pollack WS, Levant RF, editors. New Psychotherapy for Men.
Pollack WS. (1998). Real Boys: Rescuing Our Sons From the Myths of Boyhood.
Pollack WS. (1998). The trauma of Oedipus: Toward a new psychoanalytic psychotherapy for men. Pollack WS, Levant RF, editors. New Psychotherapy for Men.
Pollack WS. (2000). Real Boys' Voices.
Pollack WS. (2001). “Masked men”: New psychoanalytically oriented treatment models for adult and young adult men. Brooks G.R, Good GE, editors. The New Handbook of Psychotherapy and Counseling With Men: A Comprehensive Guide to Settings, Problems, and Treatment Approaches.
Pollack WS. (2010). Gender issues: Modern models of young male resilient mental health. Young Adult Mental Health.
Pollack WS, Levant RF. (1998). Introduction: Treating men in the 21st century. Pollack WS, Levant RF, editors. New Psychotherapy for Men.
Potts MK, Burnham MA, Wells KB. (1991). Gender differences in depression detection: A comparison of clinician diagnosis and standardized assessment. Psychological Assessment.
Powell DJ. (2003). Playing Life's Second Half A Man's Guide for Turning Success Into Significance.
Powell DJ, Brodsky A. (1998). Clinical Supervision in Alcohol and Drug Abuse Counseling: Principles, Models, Methods.
Powers MB, Vedel E, Emmelkamp PMG. (2008). Behavioral couples therapy (BCT) for alcohol and drug use disorders: A meta-analysis. Clinical Psychology Review.
Prescott CA. (2002). Sex differences in the genetic risk for alcoholism. Alcohol Health and Research World.
Pridal CG. (2001). Male gender role issues in the treatment of sexual dysfunction. The New Handbook of Psychotherapy and Counseling With Men: A Comprehensive Guide to Settings, Problems, and Treatment Approaches.
Pridemore WA. (2002). Vodka and violence: Alcohol consumption and homicide rates in Russia. American Journal of Public Health.
Prochaska JO, DiClemente CC. (1984). The stages of change. The transtheoretical approach: crossing traditional boundaries of therapy.
Public Broadcasting Service. (2002). Faith in America: Facts and Stats.
Pujazon-Zazik M, Park MJ. (2009). Marijuana: Use among young males and health outcomes. American Journal of Men's Health.
Purcell DW, Parsons JT, Halkitis PN, Mizuno Y, Woods WJ. (2001). Substance use and sexual transmission risk behavior of HIV-positive men who have sex with men. Journal of Substance Abuse.
Putnam FW. (2003). Ten-year research update review: Child sexual abuse. Journal of the American Academy of Child & Adolescent Psychiatry.
Quigley BM, Leonard KE. (2000). Alcohol and the continuation of early marital aggression. Alcoholism: Clinical and Experimental Research.
Quintero GA, Estrada A. (1998). Cultural models of masculinity and drug use: “Machismo,” heroin, and street survival on the U.S.-Mexico border. Contemporary Drug Problems.
Rabinowitz J, Marjefsky S. (1998). Predictors of being expelled from and dropping out of alcohol treatment. Psychiatric Services.
Rahav M, Nuttbrock L, Rivera JJ, Link BG. (1998). HIV infection risks among homeless, mentally ill, chemical misusing men. Substance Use and Misuse.
Ramirez RR, de la Cruz G.P. (2003). The Hispanic Population in the United States: March 2002.
Rand MR. (1997). Violence–Related Injuries Treated in Hospital Emergency Departments.
Ratner PA, Johnson JL, Shoveller JA, Chan K, Martindale SL, Schilder AJ, Botnick MR, Hogg RS. (2003). Non-consensual sex experienced by men who have sex with men: Prevalence and association with mental health. Patient Education and Counseling.
Rawson RA, Washton A, Domier CP, Reiber C. (2002). Drugs and sexual effects: Role of drug type and gender. Journal of Substance Abuse Treatment.
Raymond NC, Coleman E, Ohlerking F, Christenson G.A, Miner M. (1999). Psychiatric comorbidity in pedophilic sex offenders. American Journal of Psychiatry.
Real T. (1997). I Don't Want To Talk About It: Overcoming the Secret Legacy of Male Depression.
Reardon SF, Buka SL. (2002). Differences in onset and persistence of substance abuse and dependence among Whites, Blacks, and Hispanics. Public Health Reports.
Reid J, Macchetto P, Foster S. (1999). No Safe Haven: Children of Substance–Abusing Parents.
Reilly PM, Shopshire MS. (2000). Anger management group treatment for cocaine dependence: Preliminary outcomes. American Journal of Drug and Alcohol Abuse.
Reilly PM, Shopshire MS. (2002). Anger Management for Substance Abuse and Mental Health Clients: A Cognitive Behavioral Therapy Manual.
Reilly PM, Shopshire MS, Durazzo TC, Campbell TA. (2002). Anger Management for Substance Abuse and Mental Health Clients: Participant Workbook.
Rempel GR, Neufeld A, Kushner KE. (2007). Interactive use of genograms and ecomaps in family caregiving research. Journal of Family Nursing.
Retzinger SM. (1998). Shame in the therapeutic relationship. Gilbert P, Andrews B, editors. Shame: Interpersonal Behavior, Psychopathology, and Culture.
Rhoades ER. (2003). The health status of American Indian and Alaska native males. American Journal of Public Health.
Rich JA, Grey CM. (2005). Pathways to recurrent trauma among young Black men: Traumatic stress, substance use, and the “code of the street”. American Journal of Public Health.
Richardson A, Budd T. (2003). Young adults, alcohol, crime and disorder. Criminal Behaviour and Mental Health.
Ries RK, Fiellin DA, Miller SC, Saitz R. (2009). Principles of Addiction Medicine.
Ries RK, Dyck DG, Short R, Srebnik D, Fisher A, Comtois KA. (2004). Outcomes of managing disability benefits among patients with substance dependence and severe mental illness. Psychiatric Services.
Rietmeijer CA, Wolitski RJ, Fishbein M, Corby NH, Cohn DL. (1998). Sex hustling, injection drug use, and non–gay identification by men who have sex with men: Associations with high-risk sexual behaviors and condom use. Sexually Transmitted Diseases.
Ritsher JB, Moos RH, Finney JW. (2002). Relationship of treatment orientation and continuing care to remission among substance abuse patients. Psychiatric Services.
Robertson E, Donnermeyer JF. (1998). Patterns of drug use among nonmetropolitan and rural adults. Substance Use and Misuse.
Robertson JE. (2003). Rape among incarcerated men: Sex, coercion and STDs. AIDS Patient Care and STDs.
Robertson JM, Fitzgerald LF. (1992). Overcoming the masculine mystique: Preferences for alternative forms of assistance among men who avoid counseling. Journal of Counseling Psychology.
Robinson B. (2003). Religious Beliefs of Americans.
Robinson J, Sareen J, Cox BJ, Bolton J. (2009). Self-medication of anxiety disorders with alcohol and drugs: Results from a nationally representative sample. Journal of Anxiety Disorders.
Rodriguez-Andrew S. (1998). Alcohol use and abuse among Latinos: Issues and examples of culturally competent services. Alcoholism Treatment Quarterly.
Roehrich L, Kinder BN. (1991). Alcohol expectancies and male sexuality: Review and implications for sex therapy. Journal of Sex & Marital Therapy.
Rondinelli AJ, Ouellet LJ, Strathdee SA, Latka MH, Hudson SM, Hagan H, Garfein RS. (2009). Young adult injection drug users in the United States continue to practice HIV risk behaviors. Drug and Alcohol Dependence.
Room R, Graham K, Rehm J, Jernigan D, Monteiro M. (2003). Drinking and its burden in a global perspective: Policy considerations and options. European Addiction Research.
Rosen CS, Ouimette PC, Sheikh JI, Gregg JA, Moos RH. (2002). Physical and sexual abuse history and addiction treatment outcomes. Journal of Studies on Alcohol.
Rosen MI, Desai R, Bailey M, Davidson L, Rosenheck R. (2001). Consumer experience with payeeship provided by a community mental health center. Psychiatric Rehabilitation Journal.
Rosen MI, Rosenheck RA, Shaner A, Eckman T, Gamache G, Krebs C. (2002). Veterans who may need a payee to prevent misuse of funds for drugs. Psychiatric Services.
Rosenheck R. (1997). Disability payments and chemical dependence: Conflicting values and uncertain effects. Psychiatric Services.
Roszell DK, McFall M.E, Malas K.L. (1991). Frequency of symptoms and concurrent psychiatric disorder in Vietnam veterans with chronic PTSD. Hospital and Community Psychiatry.
Roter D, Lipkin M, Korsgaard A. (1991). Sex differences in patients' and physicians' communication during primary care medical visits. Medical Care.
Rubin A, Stout RL, Longabaugh R. (1996). Gender differences in relapse situations. Addiction.
Ruzek J. (2003). Concurrent posttraumatic stress disorder and substance use disorder among veterans: Evidence and treatment issues. Ouimette P, Brown PJ, editors. Trauma and Substance Abuse: Causes, Consequences, and Treatment of Comorbid Disorders.
Rybak CJ, Brown BM. (1996). Assessment of internalized shame: Validity and reliability of the Internalized Shame. Scale Alcoholism Treatment Quarterly.
Rychtarik RG, Connors GJ, Whitney RB, McGillicuddy N.B, Fitterling J.M, Wirtz P.W. (2000). Treatment settings for persons with alcoholism: Evidence for matching clients to inpatient versus outpatient care. Journal of Consulting and Clinical Psychology.
Saez PA, Casado A, Wade JC. (2009). Factors influencing masculinity ideology among Latino men. The Journal of Men's Studies.
Saitz R. (2009). Medical and surgical complications of addictions. Ries RK, Fiellin DA, Miller SC, Saitz R, editors. Principles of Addiction Medicine.
Sandman D, Simantov E, An C. (2000). Out of Touch: American Men and the Health Care System: Commonwealth Fund Men's and Women's Health Survey Findings.
Sandoz J. (2000). Alcoholism recovery: Myth, philosophy, and the 12 Steps. Counselor.
Satre DD, Arean PA. (2005). Effects of gender, ethnicity, and medical illness on drinking cessation in older primary care patients. Journal of Aging and Health.
Satre DD, Knight BG. (2001). Alcohol expectancies and their relationship to alcohol use: Age and sex differences. Aging & Mental Health.
Satre DD, Mertens JR, Arean PA, Weisner C. (2004). Five-year alcohol and drug treatment outcomes of older adults versus middle-aged and younger adults in a managed care program. Addiction.
Satre DD, Mertens JR, Weisner C. (2004). Gender differences in treatment outcomes for alcohol dependence among older adults. Journal of Studies on Alcohol.
Saul JE, Schillo BA, Evered S, Luxenberg MG, Kavanaugh A, Cobb N, An LC. (2007). Impact of a statewide Internet-based tobacco cessation intervention. Journal of Medical Internet Research.
Scheff TJ. (1987). The shame-rage spiral: A case study of an interminable quarrel. Lewis H.B, editor. The Role of Shame in Symptom Formation.
Scher M. (2005). Male therapist, male client: Reflections on critical dynamics. Brooks G.R, Good GE, editors. The New Handbook of Psychotherapy and Counseling With Men: A Comprehensive Guide to Settings, Problems, and Treatment Approaches.
Scherrer JF, Slutske WS, Xian H, Waterman B, Shah KR, Volberg R, Eisen SA. (2007). Factors associated with pathological gambling at 10-year follow-up in a national sample of middle-aged men. Addiction.
Schrimsher GW, Parker JD, Burke RS. (2007). Relation between cognitive testing performance and pattern of substance use in males at treatment entry. Clinical Neuropsychologist.
Schuckit MA. (1986). Primary men alcoholics with histories of suicide attempts. Journal of Studies on Alcohol.
Schuckit MA, Smith TL. (2001). A comparison of correlates of DSM-IV alcohol abuse or dependence among more than 400 sons of alcoholics and controls. Alcoholism: Clinical and Experimental Research.
Schumacher JA, Fals-Stewart W, Leonard KE. (2003). Domestic violence treatment referrals for men seeking alcohol treatment. Journal of Substance Abuse Treatment.
Schwab AJ, DiNitto D.M. (1993). Factors related to the successful vocational rehabilitation of substance abusers. Journal of Applied Rehabilitation Counseling.
Schwartz MF, Southern S. (2000). Compulsive cybersex: The new tea room. Cooper A, editor. Cybersex: The Dark Side of the Force: A Special Issue of the Journal of Sexual Addiction and Compulsion.
Schwartzman J. (1982). Normality from a cross-cultural perspective. Walsh F, editor. Normal Family Processes.
Sedlak AJ, Broadhurst DD. (1996). The Third National Incidence Study of Child Abuse and Neglect.
Semple SJ, Zians J, Grant I, Patterson TL. (2006). Methamphetamine use, impulsivity, and sexual risk behavior among HIV-positive men who have sex with men. Journal of Addictive Diseases.
Shay JJ, Maltas CP. (1998). Reluctant men in couple therapy: Corralling the Marlboro man. Pollack WS, Levant RF, editors. New Psychotherapy for Men.
Shelton S, Liljequist L. (2002). Characteristics and behaviors associated with body image in male domestic violence offenders. Eating Behaviors.
Shernoff M. (1996). Returning with AIDS: Supporting rural emigrants. Focus.
Shoptaw S. (2006). Methamphetamine use in urban gay and bisexual populations. Topics in HIV Medicine.
Siegrist J, Rodel A. (2006). Work stress and health risk behavior. Scandinavian Journal of Work Environment and Health.
Silverstein L, Auerbach C, Levant R. (2002). Contemporary fathers reconstructing masculinity: Clinical implications of gender role strain. Professional Psychology: Research and Practice.
Simoni-Wastila L, Yang HK. (2006). Psychoactive drug abuse in older adults. American Journal of Geriatric Pharmacotherapy (AJGP).
Simons L, Giorgio T. (2008). Characteristics of substance among men and women entering a drug treatment program: An exploration of sex differences. Addictive Disorders & Their Treatment.
Singer JA. (1997). Message in a Bottle: Stories of Men and Addiction.
Singer M. (1999). Why do Puerto-Rican injection drug users inject so often?. Journal of Anthropology and Medicine.
Sinha R, Easton C, Kemp K. (2003). Substance abuse treatment characteristics of probation-referred young adults in a community-based outpatient program. American Journal of Drug and Alcohol Abuse.
Skinner WF. (1994). The prevalence and demographic predictors of illicit and licit drug use among lesbians and gay men. American Journal of Public Health.
Skinner WF, Otis MD. (1996). Drug and alcohol use among lesbian and gay people in a Southern U.S. sample: Epidemiological, comparative, and methodological findings from the Trilogy Project. Journal of Homosexuality.
Smiler AP. (2004). Thirty years after the discovery of gender: Psychological concepts and measures of masculinity. Sex Roles.
Smith GS, Branas CC, Miller TR. (1999). Fatal nontraffic injuries involving alcohol: A metaanalysis. Annals of Emergency Medicine.
Smith KM, Romanelli F. (2005). Recreational use and misuse of phosphodiesterase 5 inhibitors. Journal of the American Pharmaceutical Association.
Smith TC, Wingard DL, Ryan MA, Kritz-Silverstein D, Slymen DJ, Sallis JF. (2008). Prior assault and posttraumatic stress disorder after combat deployment. Epidemiology.
Snowden LR, Hines AM. (1998). Acculturation, alcohol consumption, and AIDS-related risky sexual behavior among African American men. Journal of Community Psychology.
Snyder HN. (2000). Sexual Assault of Young Children as Reported to Law Enforcement: Victim, Incident, and Offender Characteristics.
Sobell LC, Sobell MB. (1992). Timeline followback: A technique for assessing self-reported ethanol consumption. Allen J, Litten RZ, editors. Measuring Alcohol Consumption: Psychosocial and Biological Methods.
Sogyal R. (1992). Gaffney P, Harvey A, editors. The Tibetan Book of Living and Dying.
Soldz S, Vaillant GE. (1998). A 50-year longitudinal study of defense use among inner city men: A validation of the DSM-IV defense axis. Journal of Nervous and Mental Disease.
Solomon Z, Mikulincer M. (1987). Combat stress reactions, posttraumatic stress disorder, and social adjustment: A study of Israeli veterans. Journal of Nervous and Mental Disease.
Soyka M, Schmidt P. (2009). Outpatient alcoholism treatment—24-month outcome and predictors of outcome. Substance Abuse Treatment, Prevention, and Policy.
Spielberger CD. (1999). State-Trait Anger Expression Inventory–2.
Stall R, Paul JP, Greenwood G, Pollack LM, Bein E, Crosby GM, Mills TC, Binson D, Coates TJ, Catania JA. (2001). Alcohol use, drug use and alcohol-related problems among men who have sex with men: The Urban Men's Health Study. Addiction.
Stein BD, Kogan JN, Sorbero M. (2009). Substance abuse detoxification and residential treatment among Medicaid-enrolled adults: Rates and duration of subsequent treatment. Drug and Alcohol Dependence.
Steinberg ML, Epstein EE, McCrady B.S, Hirsch L.S. (1997). Sources of motivation in a couples outpatient alcoholism treatment program. American Journal on Drug and Alcohol Abuse.
Sterling RC, Gottheil E, Glassman SD, Weinstein SP, Serota RD, Lundy A. (2001). Correlates of employment: A cohort study. American Journal of Drug and Alcohol Abuse.
Stewart SH, Kushner MG. (2003). Recent research on the comorbidity of alcoholism and pathological gambling. Alcoholism, Clinical and Experimental Research.
Stimpson NJ, Thomas HV, Weightman AL, Dunstan F, Lewis G. (2003). Psychiatric disorder in veterans of the Persian Gulf War of 1991: Systematic review. British Journal of Psychiatry.
Stout R, Del Boca F.K, Carbonari J, Rychtarik R, Litt M.D, Cooney N.L. (2003). Primary treatment outcomes and matching effects: Outpatient arm. Babor TF, Del Boca FK, editors. Treatment Matching in Alcoholism.
Strasburger LH, Gutheil TG, Brodsky A. (1997). On wearing two hats: Role conflict in serving as both psychotherapist and expert witness. American Journal of Psychiatry.
Straus MA. (1999). The controversy over domestic violence by women: A methodological, theoretical, and sociology of science analysis. Arriaga XB, Oskamp S, editors. Violence in Intimate Relationships.
Straus MA, Hamby SL, Boney-McCoy S, Sugarman DB. (1996). The Revised Conflict Tactics Scale (CTS2): Development and preliminary psychometric data. Journal of Family Issues.
Strawbridge WJ, Shema SJ, Cohen RD, Kaplan GA. (1998). Religiosity buffers effects of some stressors on depression but exacerbates others. Journals of Gerontology: Series B: Psychological Sciences and Social Sciences.
Strecher VJ, Shiffman S, West R. (2005). Randomized controlled trial of a web-based computer-tailored smoking cessation program as a supplement to nicotine patch therapy. Addiction.
Streifel C. (1997). Gender, alcohol use, and crime. Wilsnack RW, Wilsnack SC, editors. Gender and Alcohol: Individual and Social Perspectives.
Strobbe S, Brower KJ, Galen LW. (2003). Gender and outpatient detoxification from alcohol. Journal of Addictions Nursing.
Strock M. (2004). Depression.
Strowig AB. (2000). Relapse determinants reported by men treated for alcohol addiction: The prominence of depressed mood. Journal of Substance Abuse Treatment.
Struckman-Johnson CJ, Struckman-Johnson DL. (2000). Sexual coercion rates in seven Midwestern prison facilities for men. Prison Journal.
Struckman-Johnson CJ, Struckman-Johnson DL, Rucker L, Bumby K, Donaldson S. (1996). Sexual coercion reported by men and women in prison. Journal of Sex Research.
Stuart GL. (2005). Improving violence intervention outcomes by integrating alcohol treatment. Journal of Interpersonal Violence.
Substance Abuse and Mental Health Services Administration. (2003). Get Connected! Linking Older Americans With Medication, Alcohol, and Mental Health Resources.
Substance Abuse and Mental Health Services Administration. (2004). The Confidentiality of Alcohol and Drug Abuse Patient Records Regulation and the HIPAA Privacy Rule: Implications for Alcohol and Substance Abuse Programs.
Substance Abuse and Mental Health Services Administration. (2005). Results From the 2004 National Survey on Drug Use and Health: National Findings.
Substance Abuse and Mental Health Services Administration. (2008). Results From the 2007 National Survey on Drug Use and Health: National Findings.
Substance Abuse and Mental Health Services Administration. (2009). Results From the 2008 National Survey on Drug Use and Health: National Findings.
Substance Abuse and Mental Health Services Administration. (2011). Addressing Viral Hepatitis in People With Substance Use Disorders.
Substance Abuse and Mental Health Services Administration. (2011). Managing Chronic Pain in Adults With or in Recovery From Substance Use Disorders.
Substance Abuse and Mental Health Services Administration. (2013). Behavioral Health Services for People Who Are Homeless.
Substance Abuse and Mental Health Services Administration. Behavioral Health Services for American Indians and Alaska Natives.
Substance Abuse and Mental Health Services Administration. Building Health, Wellness, and Quality of Life for Sustained Recovery.
Substance Abuse and Mental Health Services Administration. Improving Cultural Competence.
Substance Abuse and Mental Health Services Administration. Managing Anxiety Symptoms in Behavioral Health Services.
Substance Abuse and Mental Health Services Administration. Recovery in Behavioral Health Services.
Substance Abuse and Mental Health Services Administration. Reintegration-Related Behavioral Health Issues in Veterans and Military Families.
Substance Abuse and Mental Health Services Administration. Trauma-Informed Care in Behavioral Health Services.
Substance Abuse and Mental Health Services Administration. Using Telephone- and Web-Based Technologies in Behavioral Health Settings.
Substance Abuse and Mental Health Services Administration, Office of Applied Studies. (2004). Results From the 2003 National Survey on Drug Use and Health: National Findings.
Substance Abuse and Mental Health Services Administration, Office of Applied Studies. (2004). Treatment Episode Data Set (TEDS): 1992–2002. National Admissions to Substance Abuse Treatment Services.
Substance Abuse and Mental Health Services Administration, Office of Applied Studies. (2007). Male Admissions With Co-Occurring Psychiatric and Substance Use Disorders: 2005.
Substance Abuse and Mental Health Services Administration, Office of Applied Studies. (2007). Gender Differences in Alcohol Use and Alcohol Dependence or Abuse: 2004 and 2005.
Substance Abuse and Mental Health Services Administration, Office of Applied Studies. (2007). Male Admissions With Co-Occurring Psychiatric and Substance Use Disorders: 2005.
Substance Abuse and Mental Health Services Administration, Office of Applied Studies. (2007). The National Survey of Substance Abuse Treatment Services (N-SSATS): 2006.
Substance Abuse and Mental Health Services Administration, Office of Applied Studies. (2008). Drug Abuse Warning Network, 2006: National Estimates of Drug-Related Emergency Department Visits.
Substance Abuse and Mental Health Services Administration, Office of Applied Studies. (2008). Treatment Episode Data Set (TEDS) Highlights: 2006. National Admissions to Substance Abuse Treatment Services.
Substance Abuse and Mental Health Services Administration, Office of Applied Studies. (2009). The TEDS Report: Predictors of Substance Abuse Treatment Completion or Transfer to Further Treatment by Service Type.
Substance Abuse and Mental Health Services Administration, Office of Applied Studies. (2009). The TEDS Report: Treatment Outcomes Among Clients Discharged From Outpatient Substance Abuse Treatment.
Substance Abuse and Mental Health Services Administration, Office of Applied Studies. (2009). The TEDS Report: Trends in Meth amphetamine Admissions to Treatment: 1997–2007.
Suddaby K, Landau J. (1998). Positive and negative timelines: A technique for restorying. Family Process.
Sue DW, Sue D. (2008). Counseling the Culturally Diverse: Theory and Practice.
Swartz JA, Lurigio AJ. (1999). Psychiatric illness and comorbidity among adult male jail detainees in drug treatment. Psychiatric Services.
Tafrate RC, Kassinove H, Dundin L. (2002). Anger episodes in high and low trait anger community adults. Journal of Clinical Psychology.
Taft CT, Kaloupek DG, Schumm JA, Marshall AD, Panuzio J, King DW, Keane TM. (2007). Posttraumatic stress disorder symptoms, physiological reactivity, alcohol problems, and aggression among military veterans. Journal of Abnormal Psychology.
Takeuchi DT, Sue S, Yeh M. (1995). Return rates and outcomes from ethnicity-specific mental health programs in Los Angeles. American Journal of Public Health.
Takeuchi DT, Zane N, Hong S, Chae DH, Gong F, Gee GC, Walton E, Sue S, Alegria M. (2007). Immigration-related factors and mental disorders among Asian Americans. American Journal of Public Health.
Tangney JP, Dearing RL. (2002). Shame and Guilt.
Taylor B. (1999). “Coming out” as a life transition: Homosexual identity formation and its implications for health care practice. Journal of Advanced Nursing.
Temple MT, Fillmore KM, Hartka E, Johnstone B, Leino EV, Motoyoshi M. (1991). A meta-analysis of change in marital and employment status as predictors of alcohol consumption on a typical occasion. British Journal of Addiction.
Thorn B. (2003). Risk-Taking Behaviour in Men: Substance Use and Gender.
Thomas EJ, Ager RD. (1993). Unilateral family therapy with spouses of uncooperative alcohol abusers. O'Farrell T.G, editor. Treating Alcohol Problems: Marital and Family Interventions.
Thompkins CD, Rando RA. (2003). Gender role conflict and shame in college men. Psychology of Men and Masculinity.
Thompson EH, Pleck JH. (1986). The structure of male role norms. American Behavioral Scientist.
Thompson EH, Pleck JH. (1995). Masculinity ideologies: A review of research instrumentation on men and masculinities. Levant RF, Pollack WS, editors. A New Psychology of Men.
Thompson RA, Nored LS, Cheeseman DK. (2008). The Prison Rape Elimination Act (PREA): An evaluation of policy compliance with illustrative excerpts. Criminal Justice Policy Review.
Thompson V.L.S, Talley M, Caito N, Kreuter M. (2009). African American men's perceptions of factors influencing health information-seeking. American Journal of Men's Health.
Tiet QQ, Ilgen MA, Byrnes HF, Harris AH, Finney JW. (2007). Treatment setting and baseline substance use severity interact to predict patients' outcomes. Addiction.
Timko C, DeBenedetti A. (2007). A randomized controlled trial of intensive referral to 12-Step self-help groups: One-year outcomes. Drug and Alcohol Dependence.
Timko C, Finney JW, Moos RH. (2005). The 8-year course of alcohol abuse: Gender differences in social context and coping. Alcoholism, Clinical and Experimental Research.
Timko C, Moos BS, Moos RH. (2009). Gender differences in 16-year trends in assault- and police-related problems due to drinking. Addictive Behaviors.
Timms D. (1998). Gender, social mobility and psychiatric diagnoses. Social Science and Medicine.
Tivis LJ, Parsons OA, Nixon SJ. (1998). Anger in an inpatient treatment sample of chronic alcoholics. Alcoholism: Clinical and Experimental Research.
Tjaden P, Thoennes N. (2000). Extent, Nature, and Consequences of Intimate Partner Violence: Findings From the National Violence Against Women Survey.
Tonigan JS. (2003). Project Match treatment participation and outcome by self-reported ethnicity. Alcoholism, Clinical and Experimental Research.
Torres JB. (1998). Masculinity and gender roles among Puerto Rican men: Machismo on the U.S. mainland. American Journal of Orthopsychiatry.
Torres JB, Solberg VS, Carlstrom AH. (2002). The myth of sameness among Latino men and their machismo. American Journal of Orthopsychiatry.
Towle S. (2002). Steve's Story: No Access to Treatment.
Tracy SW, Trafton JA, Humphreys K. (2004). The Department of Veterans Affairs Substance Abuse Treatment System: Results of the 2003 Drug and Alcohol Program Survey.
Treise D, Wolburg JM, Otnes CC. (1999). Understanding the “social gifts” of drinking rituals: An alternative framework for PSA developers. Journal of Advertising.
Trenton AJ, Currier GW. (2005). Behavioural manifestations of anabolic steroid use. CNS Drugs.
Trocmé N, MacLaurin B, Fallon B, Daciuk J, Billingsley D, Tourigny M, Mayer M, Wright J, Barter K, Burford G, Hornick J, Sullivan R, McKenzie B. (2001). Canadian Incidence Study of Reported Child Abuse and Neglect: Final Report.
Tu GC, Israel Y. (1995). Alcohol consumption by Orientals in North America is predicted largely by a single gene. Behavior Genetics.
United Nations Economic Commission for Europe. (2004). Crime and Violence—Perpetrators and Types of Crime–Gender Issues.
U.S. Census Bureau. (2004). Hispanic and Asian Americans Increasing Faster Than Overall Population.
U.S. Department of Health and Human Services. (1999). Mental Health: A Report of the Surgeon General.
U.S. Department of Health and Human Services. (2007). The Surgeon General's Call to Action To Prevent and Reduce Underage Drinking.
U.S. Department of Health and Human Services, Administration for Children and Families. (2009). Child Maltreatment, 2007.
U.S. Department of Health and Human Services, Substance Abuse and Mental Health Services Administration, Office of Applied Studies. (2000). National Household Survey on Drug Abuse, 1998.
U.S. Department of Health and Human Services, Substance Abuse and Mental Health Services Administration, Office of Applied Studies. (2007). National Survey on Drug Use and Health, 2006.
U.S. Department of Health and Human Services, Substance Abuse and Mental Health Services Administration, Office of Applied Studies. (2008). National Survey on Drug Use and Health, 2007.
U.S. Department of Health and Human Services, Substance Abuse and Mental Health Services Administration, Office of Applied Studies. (2008). Treatment Episode Data Set (TEDS), 2006.
U.S. Department of Health and Human Services, Substance Abuse and Mental Health Services Administration, Office of Applied Studies. (2009). Treatment Episode Data Set (TEDS), 2007.
US Department of Health and Human Services, Substance Abuse and Mental Health Services Administration, Office of Applied Studies. (2009). National Survey on Drug Use and Health, 2008.
U.S. Department of Justice. (2008). Criminal Victimization in the United States, 2006: Statistical Tables.
U.S. Public Health Service. (1999). The Surgeon General's Call to Action To Prevent Suicide.
Vaillant GE. (1996). A long-term follow-up of male alcohol abuse. Archives of General Psychiatry.
Vaillant GE. (2005). Alcoholics Anonymous: Cult or cure?. Australian and New Zealand Journal of Psychiatry.
Vaillant GE, Hiller-Sturmhofel S. (1996). The natural history of alcoholism. Alcohol Health and Research World.
Van TH, Koblin BA. (2009). HIV, alcohol, and noninjection drug use. Current Opinion in HIV and AIDS.
Vandello JA, Bosson JK, Cohen D, Burnaford RM, Weaver JR. (2008). Precarious manhood. Journal of Personality and Social Psychology.
van Etten ML, Neumark YD, Anthony JC. (1999). Male-female differences in the earliest stages of drug involvement. Addiction.
van Oers JAM, Bongers IMB, Van de Goor LAM, Garretsen HFL. (1999). Alcohol consumption, alcohol-related problems, problem drinking, and socioeconomic status. Alcohol and Alcoholism.
van Wormer K. (1989). The male-specific group in alcoholism treatment. Small Group Behavior.
Vega WA, Alderete E, Kolody B, Aguilar-Gaxiola S. (1998). Illicit drug use among Mexicans and Mexican Americans in California: The effects of gender and acculturation. Addiction.
Vega WA, Gil AG, Zimmerman RS. (1993). Patterns of drug use among Cuban American, African American, and White non-Hispanic boys. American Journal of Public Health.
Vesga-Lopez O, Schneier FR, Wang S, Heimberg R.G, Liu S.M, Hasin D.S, Blanco C. (2008). Gender differences in generalized anxiety disorder: Results from the National Epidemiologic Survey on Alcohol and Related Conditions (NESARC). Journal of Clinical Psychiatry.
Veterans Health Administration. (1996). VHA Program Guide 1103.1: Substance Abuse Treatment. Standards for a Continuum of Care.
Vogel DL, Wade NG, Haake S. (2006). Measuring the self-stigma associated with seeking psychological help. Journal of Counseling Psychology.
von Sydow K, Lieb R, Pfister H, Hofler M, Sonntag H, Wittchen HU. (2001). The natural course of cannabis use, abuse and dependence over four years: A longitudinal community study of adolescents and young adults. Drug and Alcohol Dependence.
von Sydow K, Lieb R, Pfister H, Hofler M, Wittchen HU. (2002). Use, abuse and dependence of ecstasy and related drugs in adolescents and young adults: A transient phenomenon? Results from a longitudinal community study. Drug and Alcohol Dependence.
Wade JC. (1994). Substance abuse: Implications for counseling African American men. Journal of Mental Health Counseling.
Wade JC. (2009). Traditional masculinity and African American men's health-related attitudes and behaviors. American Journal of Men's Health.
Wagenaar AC, Toomey TL. (2000). Alcohol policy: Gaps between legislative action and current research. Contemporary Drug Problems.
Waldron I. (2005). Gender differences in mortality—causes and variation in different societies. Conrad P, editor. The Sociology of Health and Illness: Critical Perspectives.
Walfish S, Massey R, Krone A. (1990). Anxiety and anger among abusers of different substances. Drug and Alcohol Dependence.
Walitzer KS, Dearing RL. (2006). Gender differences in alcohol and substance use relapse. Clinical Psychology Review.
Walton MA, Blow FC, Booth BM. (2001). Diversity in relapse prevention needs: Gender and race comparisons among substance abuse treatment patients. American Journal of Drug and Alcohol Abuse.
Warner BD, Leukefeld CG. (2001). Rural-urban differences in substance use and treatment utilization among prisoners. American Journal of Drug and Alcohol Abuse.
Washton AM. (2009). Cocaine, Methamphetamine, and Compulsive Sexuality.
Watt TT. (2008). The race/ethnic age crossover effect in drug use and heavy drinking. Journal of Ethnicity in Substance Abuse.
Webster CD, Douglas KS, Eaves D, Hart SD. (1997). Assessing risk of violence to others. Webster CD, Jackson MA, editors. Impulsivity: Theory, Assessment, and Treatment.
Webster JM, Pimentel JH, Clark DB. (2008). Characteristics of DUI offenders convicted in wet, dry, and moist counties. Accident Analysis and Prevention.
Weidel JJ, Provencio-Vasquez E, Grossman J. (2008). Sex and drugs: High-risk behaviors at circuit parties. American Journal of Men's Health.
Weinberg MS, Williams CJ. (1974). Male Homosexuals: Their Problems and Adaptations.
Weingartner K, Robison J, Fogel D, Gruman C. (2002). Depression and substance use in a middle-aged and older Puerto Rican population. Journal of Cross-Cultural Gerontology.
Weinsheimer RL, Schermer CR, Malcoe LH, Balduf LM, Bloomfield LA. (2005). Severe intimate partner violence and alcohol use among female trauma patients. Journal of Trauma.
Weinstein SP, Gottheil E, Sterling RC. (1997). Randomized comparison of intensive outpatient vs. individual therapy for cocaine abusers. Journal of Addictive Diseases.
Weinstock J, Barry D, Petry NM. (2008). Exercise-related activities are associated with positive outcome in contingency management treatment for substance use disorders. Addictive Behaviors.
Weinstock LS. (1999). Gender differences in the presentation and management of social anxiety disorder. Journal of Clinical Psychiatry.
Weisner C, Matzger H, Kaskutas L.A. (2003). How important is treatment? One-year outcomes of treated and untreated alcohol-dependent individuals. Addiction.
Weisner C, Mertens J, Parthasarathy S, Moore C, Lu Y. (2001). Integrating primary medical care with addiction treatment: A randomized controlled trial. Journal of the American Medical Association.
Weiss RD, Griffin ML, Gallop RJ, Najavits LM, Frank A, Crits-Christoph P, Thase ME, Blaine J, Gastfriend DR, Daley D, Luborsky L. (2005). The effect of 12-Step self-help group attendance and participation on drug use outcomes among cocaine-dependent patients. Drug and Alcohol Dependence.
Weiss RD, Jaffee WB, de Menil VR, Cogley CB. (2004). Group therapy for substance use disorders: What do we know?. Harvard Review of Psychiatry.
Weiss RD, Martinez-Raga J, Griffin ML, Greenfield SR, Hufford C. (1997). Gender differences in cocaine dependent patients: A 6-month follow-up study. Drug and Alcohol Dependence.
Wells K, Klap R, Koike A, Sherbourne C. (2001). Ethnic disparities in unmet need for alcoholism, drug abuse, and mental health care. American Journal of Psychiatry.
Welte JW, Barnes GM, Wieczorek WF, Tidwell M.C, Parker J.C. (2004). Risk factors for pathological gambling. Addictive Behaviors.
West LA. (2001). Negotiating masculinities in American drinking subcultures. The Journal of Men's Studies.
Wexler DB. (2009). Men in Therapy: New Approaches for Effective Treatment.
Wilcox DM. (1998). Alcoholic Thinking.
Wilcox HC, Conner KR, Caine ED. (2004). Association of alcohol and drug use disorders and completed suicide: An empirical review of cohort studies. Drug and Alcohol Dependence.
Williams RJ, Ricciardelli LA. (1999). Gender congruence in confirmatory and compensatory drinking. Journal of Psychology.
Wilson SR, Brown NL, Mejia C, Lavori P. (2002). Effects of interviewer characteristics on reported sexual behavior of California Latino couples. Hispanic Journal of Behavioral Sciences.
Windle M, Windle RC, Scheidt DM, Miller GB. (1995). Physical and sexual abuse and associated mental disorders among alcoholic inpatients. American Journal of Psychiatry.
Winkelman M. (2003). Complementary therapy for addiction: “Drumming out drugs”. American Journal of Public Health.
Winkler D, Pjrek E, Heiden A, Wiesegger G, Klein N, Konstantinidis A, Kasper S. (2004). Gender differences in the psychopathology of depressed inpatients. European Archives of Psychiatry and Clinical Neuroscience.
Wolfe J, Martinez R, Scott WA. (1998). Baseball and beer: An analysis of alcohol consumption patterns among male spectators at major-league sporting events. Annals of Emergency Medicine.
Wolin SJ, Bennett LA. (1984). Family rituals. Family Process.
Wong FY, Huang Z.J, Thompson E.E, De Leon J.M, Shah M.S, Park R.J, Do T.D. (2007). Substance use among a sample of foreign- and U.S.-born Southeast Asians in an urban setting. Journal of Ethnicity in Substance Abuse.
Wong YJ, Pituch KA, Rochlen AB. (2006). Men's restrictive emotionality: An investigation of associations with other emotion-related constructs, anxiety, and underlying dimensions. Psychology of Men & Masculinity.
World Health Organization. (2004). The World Health Report: 2004. Changing History.
Wu LT, Kouzis AC, Leaf PJ. (1999). Influence of comorbid alcohol and psychiatric disorders on utilization of mental health services in the National Comorbidity Survey. American Journal of Psychiatry.
Yalom ID. (1980). Existential Psychotherapy.
Yeom HS, Shepard DS. (2007). Cost-effectiveness of a mixed-gender aftercare program for substance abuse: Decomposing measured and unmeasured gender differences. Journal of Mental Health Policy and Economics.
Zemishlany Z, Aizenberg D, Weizman A. (2001). Subjective effects of MDMA (“ecstasy”) on human sexual function. European Psychiatry.
Zemore SE. (2005). Re-examining whether and why acculturation relates to drinking outcomes in a rigorous, national survey of Latinos. Alcoholism, Clinical and Experimental Research.
Zemore SE. (2008). An overview of spirituality in AA (and recovery). Galanter M, Kaskutas LA, editors. Recent Developments in Alcoholism: Research on Alcoholics Anonymous and Spirituality in Addiction Recovery.
Zerger S. (2002). Substance Abuse Treatment: What Works for Homeless People? A Review of the Literature.
Zhang Z, Huang LX, Brittingham AM. (1999). Worker Drug Use and Workplace Policies and Programs: Results From the 1994 and 1997 National Household Survey on Drug Abuse.
Zickler P. (2003). Nicotine's multiple effects on the brain's reward system drive addiction. NIDA Notes.
Zielinski DS. (2009). Child maltreatment and adult socioeconomic well-being. Child Abuse and Neglect.
Zilberman ML, Tavares H, Andrade AG, el-Guebaly N. (2003). The impact of an outpatient program for women with substance use-related disorders on retention. Substance Use and Misuse.
Zlotnick C, Clarke JG, Friedmann PD, Roberts MB, Sacks S, Melnick G. (2008). Gender differences in comorbid disorders among offenders in prison substance abuse treatment programs. Behavioral Sciences & the Law.
Zuckerman M. (1979). Sensation Seeking: Beyond the Optimal Level of Arousal.
Zuckerman M. (1984). Sensation seeking: A comparative approach to a human trait. Behavioral and Brain Sciences.
Zuckerman M. (1994). Behavioral Expressions and Biosocial Bases of Sensation Seeking.
Zywiak WH, Stout RL, Longabaugh R, Dyck I, Connors GJ, Maisto SA. (2006). Relapse-onset factors in Project MATCH: The Relapse Questionnaire. Journal of Substance Abuse Treatment.
Zywiak WH, Stout RL, Trefry WB, Glasser I, Connors GJ, Maisto SA, Westerberg VS. (2006). Alcohol relapse repetition, gender, and predictive validity. Journal of Substance Abuse Treatment.