# Links to Select Abstracts

Alford DP, LaBelle CT, Richardson JM, O’Connell JJ, Hohl CA, Cheng DM, et al. Treating homeless opioid dependent patients with buprenorphine in an office-based setting. Journal of General Internal Medicine. 2007;22:171-176. [pmid: 17356982].
Backer TE, Howard EA. Cognitive impairments and the prevention of homelessness: Research and practice review. Journal of Primary Prevention. 2007;28:375-388. [pmid: 17549638].
Ball SA, Cobb-Richardson P, Connolly AJ, Bujosa CT, O’Neall TW. Substance abuse and personality disorders in homeless drop-in center clients: Symptom severity and psychotherapy retention in a randomized clinical trial. Comprehensive Psychiatry. 2005;46:371-379. [pmid: 16122538].
Benda BB. A study of substance abuse, traumata, and social support systems among homeless veterans. Journal of Human Behavior in the Social Environment. 2005;12:59-82.
Bernstein J, Bernstein E, Tassiopoulos K, Heeren T, Levenson S, Hingson R. Brief motivational intervention at a clinic visit reduces cocaine and heroin use. Drug and Alcohol Dependence. 2005;77:49-59. [pmid: 15607841].
Bird CE, Jinnett KJ, Burnam MA, Koegel P, Sullivan G, Wenzel SL, et al. Predictors of contact with public service sectors among homeless adults with and without alcohol and other drug disorders. Journal of Studies on Alcohol. 2002;63:716-725. [pmid: 12529072].
Blanchon T, Boissonnas A, Varescon I, Vidal-Trecan G. Homelessness and high-dosage buprenorphine misuse. Substance Use & Misuse. 2003;38:429-442. [pmid: 12747392].
Booth BM, Sullivan G, Koegel P, Burnam A. Vulnerability factors for homelessness associated with substance dependence in a community sample of homeless adults. American Journal of Drug and Alcohol Abuse. 2002;28:429-452. [pmid: 12211359].
Bradford DW, Gaynes BN, Kim MM, Kaufman JS, Weinberger M. Can shelter-based interventions improve treatment engagement in homeless individuals with psychiatric and/or substance misuse disorders? A randomized controlled trial. Medical Care. 2005;43:763-768. [pmid: 16034289].
Caton CL, Dominguez B, Schanzer B, Hasin DS, Shrout PE, Felix A, et al. Risk factors for long-term homelessness: Findings from a longitudinal study of first-time homeless single adults. American Journal of Public Health. 2005;95:1753-1759. [pmid: 16131638].
Cheng AL, Lin H, Kasprow W, Rosenheck RA. Impact of supported housing on clinical outcomes: Analysis of a randomized trial using multiple imputation technique. Journal of Nervous and Mental Disease. 2007;195:83-88. [pmid: 17220745].
Coldwell CM, Bender WS. The effectiveness of assertive community treatment for homeless populations with severe mental illness: A meta-analysis. American Journal of Psychiatry. 2007;164:393-399. [pmid: 17329462].
Conrad KJ, Hultman CI, Pope AR, Lyons JS, Baxter WC, Daghestani AN, et al. Case managed residential care for homeless addicted veterans: Results of a true experiment. Medical Care. 1998;36:40-53. [pmid: 9431330].
Cox GB, Walker RD, Freng SA, Short BA, Meijer L, Gilchrist L. Outcome of a controlled trial of the effectiveness of intensive case management for chronic public inebriates. Journal of Studies on Alcohol. 1998;59:523-532. [pmid: 9718104].
Crane M, Byrne K, Fu R, Lipmann B, Mirabelli F, Rota-Bartelink A, et al. The causes of homelessness in later life: Findings from a 3-nation study. Journals of Gerontology Series B: Psychological Sciences and Social Sciences. 2005;60:S152-S159.
Culhane DP, Avery JM, Hadley TR. Prevalence of treated behavioral disorders among adult shelter users: A longitudinal study. American Journal of Orthopsychiatry. 1998;68:63-72. [pmid: 9494643].
Culhane DP, Metraux S, Hadley T. Public service reductions associated with placement of homeless persons with severe mental illness in supportive housing. Housing Policy Debate. 2002;13:107-163.
Essock SM, Mueser KT, Drake RE, Covell NH, McHugo GJ, Frisman LK, et al. Comparison of ACT and standard case management for delivering integrated treatment for co-occurring disorders. Psychiatric Services. 2006;57:185-196. [pmid: 16452695].
Forney JC, Lombardo S, Toro PA. Diagnostic and other correlates of HIVrisk behaviors in a probability sample of homeless adults. Psychiatric Services. 2007;58:92-99. [pmid: 17215418].
Freund PD, Hawkins DW. What street people reported about service access and drug treatment. Journal of Health and Social Policy. 2004;18:87-93. [pmid: 15201120].
Garibaldi B, Conde-Martel A, O’Toole TP. Self-reported comorbidities, perceived needs, and sources for usual care for older and younger homeless adults. Journal of General Internal Medicine. 2005;20:726-730. [pmid: 16050882].
Gonzalez G, Rosenheck RA. Outcomes and service use among homeless persons with serious mental illness and substance abuse. Psychiatric Services. 2002;53:437-446. [pmid: 11919357].
Greenberg GA, Rosenheck RA. Correlates of past homelessness in the National Epidemiological Survey on Alcohol and Related Conditions. Administration and Policy in Mental Health. 2010;37:357-366. [pmid: 19763814].
Greenberg GA, Rosenheck RA. Mental health correlates of past homelessness in the National Comorbidity Study Replication. Journal of Health Care for the Poor and Underserved. 2010;21:1234-1249. [pmid: 21099075].
Greenwood RM, Schaefer-McDaniel NJ, Winkel G, Tsemberis SJ. Decreasing psychiatric symptoms by increasing choice in services for adults with histories of homelessness. American Journal of Community Psychology. 2005;36:223-238. [pmid: 16389497].
Herman DB, Susser ES, Struening EL, Link BL. Adverse childhood experiences: Are they risk factors for adult homelessness?. American Journal of Public Health. 1997;87:249-255. [pmid: 9103105].
Hwang SW, Kirst MJ, Chiu S, Tolomiczenko G, Kiss A, Cowan L, et al. Multidimensional social support and the health of homeless individuals. Journal of Urban Health. 2009;86:791-803. [pmid: 19629703].
Kashner TM, Rosenheck R, Campinell AB, Suris A, Crandall R, Garfield NJ, et al. Impact of work therapy on health status among homeless, substance-dependent veterans: A randomized controlled trial. Archives of General Psychiatry. 2002;59:938-944. [pmid: 12365881].
Kasprow WJ, Rosenheck RA. Outcomes of critical time intervention case management of homeless veterans after psychiatric hospitalization. Psychiatric Services. 2007;58:929-935. [pmid: 17602008].
Kertesz SG, Mullins AN, Schumacher JE, Wallace D, Kirk K, Milby JB. Long-term housing and work outcomes among treated cocaine-dependent homeless persons. Journal of Behavioral Health Services & Research. 2007;34:17-33. [pmid: 17171458].
Kertesz SG, Horton NJ, Friedmann PD, Saitz R, Samet JH. Slowing the revolving door: Stabilization programs reduce homeless persons’ substance use after detoxification. Journal of Substance Abuse Treatment. 2003;24:197-207. [pmid: 12810140].
Kertesz SG, Larson MJ, Cheng DM, Tucker JA, Winter M, Mullins A, et al. Need and non-need factors associated with addiction treatment utilization in a cohort of homeless and housed urban poor. Medical Care. 2006;44:225-233. [pmid: 16501393].
Kingree JB, Stephens T, Braithwaite R, Griffin J. Predictors of homelessness among participants in a substance abuse treatment program. American Journal of Orthopsychiatry. 1999;69:261-266. [pmid: 10234392].
Kirby MW, Braucht GN, Brown E, Krane S, McCann M, VanDeMark N. Dyadic case management as a strategy for prevention of homelessness among chronically debilitated men and women with alcohol and drug dependence. Alcoholism Treatment Quarterly. 1999;17:53-71.
Kraybill K, Zerger S. 2003. Providing treatment for homeless people with substance use disorders: Case studies of six programs. Nashville, TN. National Health Care for the Homeless Council.
Kuhn R, Culhane DP. Applying cluster analysis to test a typology of homelessness by pattern of shelter utilization: Results from the analysis of administrative data. American Journal of Community Psychology. 1998;26:207-232. [pmid: 9693690].
Kyle T, Dunn JR. Effects of housing circumstances on health, quality of life and healthcare use for people with severe mental illness: A review. Health & Social Care in the Community. 2008;16:1-15. [pmid: 18181811].
Lam JA, Jekel JF, Thompson KS, Leaf PJ, Hartwell SW, Florio L. Assessing the value of a short-term residential drug treatment program for homeless men. Journal of Addictive Diseases. 1995;14:21-39. [pmid: 8929931].
Lester KM, Milby JB, Schumacher JE, Vuchinich R, Person S, Clay OJ. Impact of behavioral contingency management intervention on coping behaviors and PTSD symptom reduction in cocaine-addicted homeless. Journal of Traumatic Stress. 2007;20:565-575. [pmid: 17721968].
Lewis JR, Boyle DP, Lewis LS, Evans M. Reducing AIDS and substance abuse risk factors among homeless, HIV-infected, drug-using persons. Research on Social Work Practice. 2000;10:15-33.
Mares A, Rosenheck R. Twelve-month client outcomes and service use in a multisite project for chronically homelessness adults. Journal of Behavioral Health Services & Research. 2010;37:167-183. [pmid: 19350394].
Martinez TE, Burt MR. Impact of permanent supportive housing on the use of acute care health services by homeless adults. Psychiatric Services. 2006;57:992-999. [pmid: 16816284].
McNamara C, Schumacher JE, Milby JB, Wallace D, Usdan S. Prevalence of nonpsychotic mental disorders does not affect treatment outcome in a homeless cocaine-dependent sample. American Journal of Drug and Alcohol Abuse. 2001;27:91-106. [pmid: 11373038].
McNiel DE, Binder RL, Robinson JC. Incarceration associated with homelessness, mental disorder, and co-occurring substance abuse. Psychiatric Services. 2005;56:840-846. [pmid: 16020817].
Milby JB, Schumacher JE, Vuchinich RE, Freedman MJ, Kertesz S, Wallace D. Toward cost-effective initial care for substance-abusing homeless. Journal of Substance Abuse Treatment. 2008;34:180-191. [pmid: 17512156].
Milby JB, Schumacher JE, Wallace D, Freedman MJ, Vuchinich RE. To house or not to house: The effects of providing housing to homeless substance abusers in treatment. American Journal of Public Health. 2005;95:1259-1265. [pmid: 15983278].
North CS, Eyrich KM, Pollio DE, Spitznagel EL. Are rates of psychiatric disorders in the homeless population changing?. American Journal of Public Health. 2004;94:103-108. [pmid: 14713706].
North CS, Pollio DE, Smith EM, Spitznagel EL. Correlates of early onset and chronicity of homelessness in a large urban homeless population. Journal of Nervous and Mental Disease. 1998;186:393-400. [pmid: 9680039].
Nuttbrock LH, Ng-Mak DS, Rahav M, Rivera JJ. Pre- and post-admission attrition of homeless, mentally ill chemical abusers referred to residential treatment programs. Addiction. 1997;92:1305-1315. [pmid: 9489047].
Nwakeze PC, Magura S, Rosenblum A. Drug problem recognition, desire for help, and treatment readiness in a soup kitchen population. Substance Use & Misuse. 2002;37:291-312. [pmid: 11913905].
Nyamathi A, Longshore D, Galaif ER, Leake B. Motivation to stop substance use and psychological and environmental characteristics of homeless women. Addictive Behaviors. 2004;29:1839-1843. [pmid: 15530726].
O’Connell M, Rosenheck R, Kasprow W, Frisman L. An examination of fulfilled housing preferences and quality of life among homeless persons with mental illness and/or substance use disorders. Journal of Behavioral Health Services & Research. 2006;33:354-365. [pmid: 16752112].
O’Toole TP, Gibbon JL, Hanusa BH, Freyder PJ, Conde AM, Fine MJ. Self-reported changes in drug and alcohol use after becoming homeless. American Journal of Public Health. 2004;94:830-835. [pmid: 15117708].
O’Toole TP, Freyder PJ, Gibbon JL, Hanusa BJ, Seltzer D, Fine MJ. ASAM patient placement criteria treatment levels: Do they correspond to care actually received by homeless substance abusing adults?. Journal of Addictive Diseases. 2004;23:1-15. [pmid: 15077836].
Orwin RG, Garrison-Mogren R, Jacobs ML, Sonnefeld LJ. Retention of homeless clients in substance abuse treatment Findings from the National Institute on Alcohol Abuse and Alcoholism Cooperative Agreement Program. Journal of Substance Abuse Treatment. 1999;17:45-66. [pmid: 10435252].
Orwin RG, Scott CK, Arieira C. Transitions through homelessness and factors that predict them: Three-year treatment outcomes. Journal of Substance Abuse Treatment. 2005;28:S23-S39. [pmid: 15797636].
Padgett DK, Gulcur L, Tsemberis S. Housing First services for people who are homeless with co-occurring serious mental illness and substance abuse. Research on Social Work Practice. 2006;16:74-83.
Pearson C, Montgomery AE, Locke G. Housing stability among homeless individuals with serious mental illness participating in Housing First programs. Journal of Community Psychology. 2009;37:404-417.
Prigerson HG, Desai RA, Mares WL, Rosenheck RA. Suicidal ideation and suicide attempts in homeless mentally ill persons. Age-specific risks of substance abuse. Social Psychiatry and Psychiatric Epidemiology. 2003;38:213-219. [pmid: 12664232].
Reardon ML, Burns AB, Preist R, Sachs-Ericsson N, Lang AR. Alcohol use and other psychiatric disorders in the formerly homeless and never homeless: Prevalence, age of onset, comorbidity, temporal sequencing, and service utilization. Substance Use & Misuse. 2003;38:601-644. [pmid: 12747399].
Rog DJ. The evidence on supported housing. Psychiatric Rehabilitation Journal. 2004;27:334-344. [pmid: 15222146].
Rosen MI, McMahon TJ, Lin H, Rosenheck RA. Effect of Social Security payments on substance abuse in a homeless mentally ill cohort. Health Services Research. 2006;41:173-191. [pmid: 16430606].
Rosenblum A, Magura S, Kayman DJ, Fong C. Motivationally enhanced group counseling for substance users in a soup kitchen: A randomized clinical trial. Drug and Alcohol Dependence. 2005;80:91-103. [pmid: 16157232].
Rosenblum A, Nuttbrock L, McQuistion H, Magura S, Joseph H. Medical outreach to homeless substance users in New York City: Preliminary results. Substance Use & Misuse. 2002;37:1269-1273. [pmid: 12180566].
Rosenheck R, Kasprow W, Frisman L, Liu-Mares W. Cost-effectiveness of supported housing for homeless persons with mental illness. Archives of General Psychiatry. 2003;60:940-951. [pmid: 12963676].
Rosenheck RA, Mares AS. Implementation of supported employment for homeless veterans with psychiatric or addiction disorders: Two-year outcomes. Psychiatric Services. 2007;58:325-333. [pmid: 17325104].
Sacks S, De Leon G, Sacks JY, McKendrick K, Brown BS. TC-oriented supported housing for homeless MICAs. Journal of Psychoactive Drugs. 2003;35:355-366. [pmid: 14621133].
Sacks S, Sacks JY, McKendrick K, Pearson FS, Banks S, Harle M. Outcomes from a therapeutic community for homeless addicted mothers and their children. Administration and Policy in Mental Health. 2004;31:313-338. [pmid: 15285208].
Schonfeld L, Dupree LW, Dickson-Euhrmann E, Royer CM, McDermott CH, Rosansky JS, et al. Cognitive-behavioral treatment of older veterans with substance abuse problems. Journal of Geriatric Psychiatry and Neurology. 2000;13:124-129. [pmid: 11001134].
Schumacher JE, Milby JB, Wallace D, Simpson C, Frison S, McNamara C, et al. Diagnostic compared with abstinence outcomes of day treatment and contingency management among cocaine-dependent homeless persons. Experimental and Clinical Psychopharmacology. 2003;11:146-157. [pmid: 12755459].
Schumacher JE, Usdan S, Milby JB, Wallace D, McNamara C. Abstinent-contingent housing and treatment retention among crack-cocaine-dependent homeless persons. Journal of Substance Abuse Treatment. 2000;19:81-88. [pmid: 10867305].
Skinner DC. A modified therapeutic community for homeless persons with co-occurring disorders of substance abuse and mental illness in a shelter: An outcome study. Substance Use & Misuse. 2005;40:483-497. [pmid: 15830731].
Smith JE, Meyers RJ, Delaney HD. The community reinforcement approach with homeless alcohol-dependent individuals. Journal of Consulting and Clinical Psychology. 1998;66:541-548. [pmid: 9642893].
Sosin MR, Bruni M. Homelessness and vulnerability among adults with and without alcohol problems. Substance Use & Misuse. 1997;32:939-968. [pmid: 9220563].
Sosin MR, Bruni M. Personal and situational perspectives on rejection of a homelessness and substance abuse program: An exploratory study. Social Work Research. 2000;24:16-27.
Sosin MR, Grossman SF. The individual and beyond: A socio-rational choice model of service participation among homeless adults with substance abuse problems. Substance Use & Misuse. 2003;38:503-549. [pmid: 12747396].
Stahler GJ, Shipley TE, Kirby KC, Godboldte C, Kerwin ME, Shandler I, et al. Development and initial demonstration of a community-based intervention for homeless, cocaine-using, African-American women. Journal of Substance Abuse Treatment. 2005;28:171-179. [pmid: 15780547].
Susser E, Valencia E, Conover S, Felix A, Tsai WY, Wyatt RJ. Preventing recurrent homelessness among mentally ill men: a critical time intervention after discharge from a shelter. American Journal of Public Health. 1997;87:256-262. [pmid: 9103106].
Tessler R, Rosenheck R, Gamache G. Comparison of homeless veterans with other homeless men in a large clinical outreach program. Psychiatric Quarterly. 2002;73:109-119. [pmid: 12025719].
Tommasello AC, Myers CP, Gillis L, Treherne LL, Plumhoff M. Effectiveness of outreach to homeless substance abusers. Evaluation and Program Planning. 1999;22:295-303.
Tsemberis S, Eisenberg RF. Pathways to housing: Supported housing for street-dwelling homeless individuals with psychiatric disabilities. Psychiatric Services. 2000;51:487-493. [pmid: 10737824].
Tsemberis S, Gulcur L, Nakae M. Housing First, consumer choice, and harm reduction for homeless individuals with a dual diagnosis. American Journal of Public Health. 2004;94:651-656. [pmid: 15054020].
Tucker JS, D’Amico EJ, Wenzel SL, Golinelli D, Elliott MN, Williamson S. A prospective study of risk and protective factors for substance use among impoverished women living in temporary shelter settings in Los Angeles County. Drug and Alcohol Dependence. 2005;80:35-43. [pmid: 16157229].
VanGeest JB, Johnson TP. Substance abuse and homelessness: Direct or indirect effects?. Annals of Epidemiology. 2002;12:455-461. [pmid: 12377422].
Wechsberg WM, Lam WK, Zule W, Hall G, Middlesteadt R, Edwards J. Violence, homelessness, and HIV risk among crack-using African-American women. Substance Use & Misuse. 2003;38:669-700. [pmid: 12747401].
Wenzel SL, Audrey BM, Koegel P, Morton SC, Miu A, Jinnett KJ, et al. Access to inpatient or residential substance abuse treatment among homeless adults with alcohol or other drug use disorders. Medical Care. 2001;39:1158-1169. [pmid: 11606870].
Wenzel SL, Tucker JS, Elliott MN, Hambarsoomians K, Perlman J, Becker K, et al. Prevalence and co-occurrence of violence, substance use and disorder, and HIV risk behavior: A comparison of sheltered and low-income housed women in Los Angeles County. Preventive Medicine. 2004;39:617-624. [pmid: 15313103].
Zlotnick C, Tam T, Bradley K. Long-term and chronic homelessness in homeless women and women with children. Social Work in Public Health. 2010;25:470-485. [pmid: 20818593].
Zlotnick C, Tam T, Robertson MJ. Disaffiliation, substance use, and exiting homelessness. Substance Use & Misuse. 2003;38:577-599. [pmid: 12747398].