# Part 2, Chapter 2

## Introduction

This chapter provides program descriptions and sample policies, procedures, and forms that support development of programming to meet the needs of people who are homeless. All documents are meant to serve as starting points; you must adapt them to suit the philosophy and procedures of your organization.

Our thanks to Deborah Fisk, LCSW, Director, Connecticut Mental Health Center Outreach and Engagement Project in New Haven, CT, and Douglas J. Warn, LCSW, Director, Project Renewal Chemical Dependence Outpatient Clinic in New York, NY, for providing some of the materials in this section. Additionally, a number of programs described below offered program descriptions illustrating different approaches to programming for homelessness.

## Organizational Approaches to Programming for Homelessness Services

Homelessness services may be provided by a variety of community-based organizations: mental health clinics, substance abuse treatment programs, developmental disability service agencies, organizations specifically concerned with housing and homelessness, or as part of the community’s criminal justice system or social service organizations. Additionally, these programs may be part of a faith-based organization, part of a national organization (such as Volunteers of America or the Salvation Army), or an element of State or local government. Few programs at the community level attempt to meet all community housing needs. Some may focus primarily on emergency homelessness needs, others on Housing First, and still others on individuals with substance use disorders or mental illness in remission.

Following are descriptions of four programs that reflect the range of available homelessness services in various communities. Their organizational scope, target population, staff size, funding, and responses to community needs differ, yet all four have their origins in an identified community need that was addressed by program development and implementation.

### Responsibility House

Responsibility House in New Orleans, LA, began in 1994 as a halfway house for people recovering from substance use disorders. The programs of Responsibility House focus on providing services to, and improving the lives of, the most underserved populations in the New Orleans area: indigent adults who have disabilities, such as substance use disorders, serious mental illness, and/or HIV/AIDS, and people who are homeless.

#### Contact person

Mike Martyn, Executive Director: 504-367-4426; mmartyn@rhousela.org

#### Programs

The Men’s Residential Treatment Program offers 3 to 6 months of treatment services in a modified therapeutic community setting for people who have substance dependence. Clients begin working on the 12 Steps, connect with sponsors, and perform community service while transitioning through four phases of treatment: discovery, primary, work search, and reentry. Funding is contracted through the State with the Jefferson Parish Human Services Authority.

Housing Opportunities for Persons With AIDS (HOPWA) programming and services are available for adult men who have substance dependence and are HIV positive. Funding comes from a U.S. Department of Housing and Urban Development (HUD) HOPWA grant to the City of New Orleans; Responsibility House is a subgrantee. Following primary treatment, those interested in living in a drug- and alcohol-free, recovery-focused setting may apply for the Sober Living Program. The program is designed for adult men who have at least 2 months of demonstrated abstinence and are employed.

Responsibility House also offers an Outpatient Treatment Program for men and women who have a substance use disorder and/or a co-occurring mental illness and who are at least 18 years old. Group, individual, and family counseling are offered for recovery from substance use disorders. Funding is from the U.S. Probation Service, Access to Recovery, private pay, and some insurance providers.

In 2000, Responsibility House began offering supportive housing to individuals and families who have disabilities and experience chronic homelessness. The goals of this program are to enable people who are homeless to maintain permanent independent housing, to assist clients in improving their financial independence and living skills, and to support clients in their quest for self-sufficiency.

#### Community collaboration

In 2011, Responsibility House was presented with an award for Outstanding Homeless Service Provider by UNITY of Greater New Orleans, the lead agency for the local Continuum of Care. Funding for the agency comes from HUD, the Jefferson Parish Community Development Block Grant, and several one-time grants from private foundations (Entergy, Orange County Foundation, and Greater New Orleans Foundation).

### Center for Urban Community Services

The Center for Urban Community Services (CUCS) of New York, NY, provides a wide range of services to help individuals and families who are homeless or were previously homeless (particularly those with behavioral or other disabling conditions) live full and satisfying lives in the community. In 2011, CUCS provided supportive housing services to 2,000 people and mental health services to 3,000 people; provided legal services, benefits, and/or other financial counseling to 5,500 adults and families at four sites, including one inside Rikers Island jail; helped 13,000 people gain access to housing and/or case management services, working under contract to city and State mental health authorities; and trained more than 3,000 service providers from 300 nonprofit organizations.

#### Contact person

Tony Hannigan, Executive Director: 212-801-3300

#### Programs

Clients’ mental health and substance use issues are addressed in an integrated manner as appropriate to the program. Street outreach and placement programs follow a strict Housing First approach, aided by motivational interviewing to address specific aspects of mental illness or substance abuse. Transitional programs maintain the same tight focus on obtaining permanent housing but are able to offer integrated psychopharmacology using onsite psychiatric and medical treatment, along with an array of evidence-based practices, including motivational interviewing, illness management and recovery, and co-occurring disorders skills groups. Permanent supportive housing programs use these same evidence-based practices to help tenants pursue a broad range of personal goals and aspirations in addition to embedded supported employment. Medical detoxification and residential rehabilitation are handled by partnering agencies. CUCS case managers follow clients entering such programs, helping inform treatment and coordinate transition planning.

#### Community collaboration

CUCS is passionate about the welfare of all its clients, the quality of all its programs, and the skills and commitment of all its staff members. Recent highlights include the agency’s lead support role in the Manhattan Outreach Consortium, which has reduced the Manhattan street homeless population by almost half by using an intensive Housing First model. The agency’s Project for Psychiatric Outreach to the Homeless recently received an American Psychiatric Association Silver Achievement Award for providing services to thousands of people who are currently homeless and people who had previously been homeless at 54 sites across the city. Another accomplishment is CUCS’s shift to a culture of evidence-based practice and continuous, data-driven quality improvement. Serious challenges remain, however. Perhaps the most important is the need to fully integrate primary medical care with mental health and substance abuse services. Even harder to solve is how to address the needs of New York City’s undocumented immigrants who are homeless, given restrictions imposed by most major funders.

### Open Arms Housing

Open Arms Housing, Inc. (OAH) of Washington, DC, provides permanent housing with ongoing supportive services for unaccompanied women who have lived on the streets or in shelters in Washington, DC. The organization is dedicated to providing permanent housing for vulnerable women who have previously been overlooked by current housing programs and services for the homeless. OAH owns a building in Northwest Washington, DC, that opened in 2009 to house 16 women who have experienced a range of mental health issues, substance use disorders, and medical conditions.

#### Contact person

Marilyn Kresky-Wolff, Executive Director: 202-525-3467

#### Program

The OAH model is unique in DC in that it operates under a Housing First approach, which holds that all individuals are entitled to safe and decent housing and that access to this housing should not be contingent on participation in services. Those services can come later, but housing is first. The OAH model is one of only a few similar programs across the country because:

- The OAH model rests on the premise that stable, safe housing is necessary to promote the physical, mental, and emotional well-being of all persons, particularly women with a history of chronic homelessness.
- OAH offers onsite supportive services that are tailored to each individual’s needs and are designed to prevent a return to homelessness.
- The building is designed to feature efficiency units with a full set of kitchen appliances and a private bathroom, and community rooms with shared phones, TVs, computers, and space for workshops, meetings, and get-togethers.
- Additionally, the building has three wheelchair-accessible units and a unit equipped for a deaf person; units like these are scarce.

Onsite services provided by staff include:

- Outreach and engagement.
- Orientation to community living and assistance in obtaining housing subsidies.
- Financial management and help with activities of daily living.
- Supportive counseling and crisis intervention.
- Linkage to mental health treatment, alcohol and drug abuse counseling, assertive treatment teams, employment counseling, day programs, volunteer opportunities, self-help groups, medical treatment, home health care, and food and clothing resources.

#### Community collaboration

During the period from the founding of the organization until its opening in 2009, OAH received:

- Financial support from the DC Department of Housing and Community Development (DHCD) via a permanent loan and a grant jointly from DHCD and the DC Department of Mental Health.
- A Supportive Housing Program grant from HUD via the DC Community Partnership for the Prevention of Homelessness.
- Critical early support from private lenders (e.g., acquisition loan from the OpenDoor Housing Fund).
- Predevelopment and construction funds from Cornerstone, Inc., construction loans from Local Initiatives Support Corporation and Enterprise Community Partners, and a capacity-building grant from the Corporation for Supportive Housing.
- Ongoing support through the DC Housing Authority’s Local Rent Supplement Program.

Open Arms has served 17 tenants. Fourteen of the initial residents are still in the building. One original resident moved out after reconnecting with family, and another moved to an apartment. No Open Arms resident has returned to homelessness.

### Project Renewal

Project Renewal in New York, NY, is designed to help people who are homeless empower themselves and leave the streets for a return to health, homes, and jobs. Since 1967, it has created innovative strategies to address the barriers that these men and women face. Services range from outreach to permanent housing and span case management, substance abuse and mental health services, primary medical care, and vocational rehabilitation.

#### Contact person

Mitchell Netburn, President and CEO: 212-620-0340

#### Programs

One innovative program of Project Renewal is In Homes Now (IHN), a Housing First model for chronically relapsing individuals who have substance use disorders and are homeless. It is designed to meet the special needs of people who have experienced long-term homelessness and have active substance use disorders. The program leases 110 apartments in the Bronx, Manhattan, and Brooklyn for participants, and a multidisciplinary team provides intensive case management, medical and mental health services, and occupational therapy, as well as socialization and recreational activities. All services are delivered in either the program office or the client’s home. Staff members receive ongoing training in motivational interviewing and trauma-informed care. The culture of the program is one of non-judgmental acceptance, and all interactions are centered on clients’ needs rather than program rules. The relationship that develops between the staff and the clients becomes a stabilizing force in the clients’ lives, allowing the staff to help guide clients toward a healthier lifestyle.

Nearly all (97 percent) tenants have remained stably housed over the past year. This success has led to the inclusion of harm-reduction beds in a key New York City–New York State supportive housing agreement. IHN operates from an office in Upper Manhattan that is viewed as a key factor for success because the office models itself after a drop-in center. Tenants come for socialization, for recreation, to meet with staff, or just to relax in a supportive community environment. Another program success is the ability to work with clients with co-occurring disorders and cognitive impairments. The team’s psychiatric nurse practitioners treat such clients (about 75 percent), allowing integration of treatment for mental illness with other services. Occupational therapists help clients who have never lived independently master activities of daily living.

#### Community collaboration

Clients in In Homes Now are linked to community hospitals, methadone programs, and outpatient clinics. About 25 percent of clients are veterans and receive services at the local VA medical center. Funding is received from HUD, the Substance Abuse and Mental Health Services Administration, and the New York City Department of Health and Mental Hygiene.

## Sample Policies and Procedures

As your organization increasingly provides services to people who are homeless, the need for policies and procedures to cover staff members working off site, dealing with other community agencies and partners, and responding to situations that are new to your organization will become clear. The policies and procedures presented in this section may alert you to areas where your organization needs additional guidelines. They refer to safety outside the office (for example, the “No Heroes Policy”), safety during outreach activities, client transportation, and handling medical and psychiatric emergencies in outreach settings. A sample memorandum of understanding (MOU) is also included at the end of this chapter.

### No Heroes Policy

#### Policy

[Name of program] recognizes the need to address the safety of clinical and case management staff persons who deliver services to clients outside of the organization setting and to provide resources to facilitate safe practice.

#### Procedures

- A wide range of service activities are undertaken outside the office by clinical and case management staff affiliated with the [name of program]. Community-based work with clients includes, but is not limited to:
  – Services within other organizations and agencies (e.g., Social Security, residential facilities, primary care clinics, drop-in centers).
  – Services in public settings (e.g., grocery store, coin-operated laundry facility, library).
  – Offsite groups or community outings (e.g., theater, picnics).
  – Home visits.
  – Walks with clients.
  – Street-level outreach (e.g., city green, under bridges).
  – Outreach to shelters, soup kitchens, etc.
  – Crisis intervention to known and unknown individuals.
  – Transporting clients.
  – Medicating clients in the community.
- The safety of any plan to provide service to a client in the community must be carefully assessed before undertaking the planned service. Base the number of workers and other resources needed to facilitate safety upon consideration of the following:
  – The extent to which staff members are familiar with the client, the client’s environment, and other people likely to be present in that environment.
  – The extent to which staff persons are familiar with the community or particular section of the community in which the service will be provided.
  – The extent to which staff persons are aware of client, environmental, or other risk factors that might contribute to unpredictability.
  – The time of day, season, and so forth during which service is to be provided.
  – The nature of the service to be provided and the client’s likely response to the service or task to be accomplished (e.g., transporting or accompanying a client to a medical or dental procedure or an appointment that may elicit distress or other unpredictable response from the client—such as a court, probation, or Department of Child and Family Services appointment).
- Routine community-based contacts with clients who are assessed to present low risk can be accomplished by an individual staff member according to the procedures outlined in this policy.
- Under no circumstances will any staff member enter any situation that is felt to be unsafe:
  – Any questions regarding the safety of an intervention or activity will be reviewed and cleared by the Director of [name of program] or his/her designee prior to undertaking the activity or intervention in question.
  – Local police will be involved in all community visits that have been assessed as having significant potential for violence.
  – When there is disagreement among the staff regarding the safety of a particular situation, the planned activity will be suspended until consultation with the Director of [name of program] or his/her designee takes place.
  – The circumstances listed below will trigger particular attention to safety concerns and will result in the abbreviation or suspension of direct clinical contact in the community, pending consultation with the Director of [name of program] or his/her designee. Such consultation will address concerns about the safety of the staff and of the client and/or others in the client’s environment or network. If further intervention is indicated, develop a plan to ensure the safety of involved staff members, including consideration of the need for police escort during:
    a. Outreach to a client who is suspected of being under the influence of nonprescribed substances at the time of contact or whose environment includes other individuals who are using substances.
    b. Outreach to a client who is suspected of or known to be carrying a weapon at the time of contact or whose environment includes individuals suspected of or known to be carrying weapons.
    c. Outreach to a client who becomes volatile or threatening during contact or in a setting in which volatile or threatening behavior is observed or anticipated.
    d. Outreach to a client who has a known history of physical violence.
- All community visits for the purpose of client contact require that workers bring an activated beeper and cellular phone.
- Established sign-out procedures will be used to facilitate awareness of staff whereabouts and attention to the safety of staff persons working outside the office setting.
- Sign-out information will include:
  – Name(s) of all staff members to be involved in outreach activity.
  – Destination.
  – Time of departure.
  – Anticipated time of return.
  – License plate number of vehicle being used.
  – Cellular phone number.
  – Beeper number (if applicable).
- If, in the course of providing community outreach, the staff begins to suspect or observe that the behavior of a client is exposing a child, elderly person, or individual served by the Department of Mental Retardation to abuse or neglect—including exposure to illicit activity or to circumstances that might imminently compromise the safety of these individuals—reports must be filed with the appropriate protective services agency according to established procedures for such reporting.
- All incidents that trigger safety concerns and/or require police/ambulance intervention will be reported to the Director of [name of program] or his/her designee immediately following the incident. Also:
  – Following interventions triggering safety concerns and/or the assistance of the police or an ambulance, staff will complete the Outreach Incident Report and an emergency response form documenting the circumstances of the need for emergency services. A review will be scheduled.
  – Team-and project-based reviews will be held as quickly as possible following all such incidents to facilitate discussion of issues related to staff safety, client treatment planning, and the interface between the project and the local police, as well as other emergency personnel.

### Ensuring Safety During Street and Community Outreach

#### Policy

Street-level and community services will be provided through an interorganizational collaboration between [name of program] and other service agencies. The following street-level and community outreach procedures will serve as addenda to those outlined in the “No Heroes Policy” and will inform the work of all outreach staff. They will be reviewed and revised yearly in collaboration with the involved network service agencies.

#### Procedures

These procedures will guide the work of project staff members providing clinical or case management services in outdoor public places, such as street corners, the public green, under highway bridges, and the like:

- The safety of all street outreach sites will be reviewed and approved by [name of program] leaders prior to providing outreach to those sites. Review will include the following factors:
  – Street outreach locations cannot be isolated and desolate. Staff members must always be visible to the street and be able to access other people (including the general public) for assistance in a crisis situation.
  – The time of day is relevant to the safety of any specific street outreach site.
  – Differing numbers of staff members may be required to sustain safety at any particular outreach site.
  – Safety issues known to exist in the general area of any specific outreach site may vary.
- The safety of all approved outreach sites will be reviewed quarterly and as needed so that changes in the safety of specific sites are reflected in the day-to-day list of approved outreach sites.
- Street-level outreach may be conducted from 7:00 a.m. until 8:00 p.m.
  – Between 7:00 a.m. and 4:00 p.m., conduct street-level outreach with at least two staff members.
  – Between 4:00 p.m. and 8:00 p.m., conduct street-level outreach with at least three staff members; one stays in the driver’s seat of the outreach vehicle.
  – Street outreach to individuals with whom the outreach staff has little or no familiarity will be guided by the following principles:
    a. Such individuals will not be invited into an organization vehicle for purposes of engaging in an interview or for the provision of transportation.
    b. Efforts will be made to interview such individuals in community agencies or public buildings (e.g., the library, a train station) instead of on public streets.

The following procedures will guide the provision of clinical and case management services that take place inside community settings (e.g., local shelters, soup kitchens, train stations, public libraries):

- All indoor sites will be established in collaboration between the [name of program] leaders and the proposed community organization sites before using those sites for outreach. The safety of each proposed community outreach site depends upon the following factors:
  – The community organization must agree to have outreach staff members visit their site.
  – A contact person must be identified within each community organization and must be available to outreach workers when they are on site to provide support.
  – The community organization must agree to allow workers telephone access for emergencies.

The following guidelines apply to outreach and clinical/case management services provided in either outdoor locations or specified indoor community sites:

- At least one member of the outreach team will have an activated beeper and cellular phone.
- Street-level outreach activities may be conducted in [name of program] vehicles. [Name of program] staff can be granted permission to drive the vehicles through a process initiated by the Director of the [name of program]. Use of vehicles belonging to any one of the involved affiliated organizations will be guided by the policies and procedures established by that organization.
- Outreach activities will end if any outreach team member indicates serious concerns about the safety of any particular activity.

All outreach workers will receive yearly project-based training in clinical and community safety, and they will be eligible to participate in the Clinical Safety Training offered at [name of program], regardless of organization affiliation.

### Client Transport Policies and Procedures

#### Policy

The Director of [name of program] will establish procedures to guide staff decisionmaking regarding the transport of clients to enhance both the safety of the staff members providing transportation services and the safety of the clients they transport. This policy will serve as an addendum to the “No Heroes Policy.”

#### Procedures

- Organization vehicles may be driven only by staff persons who possess valid State drivers’ licenses.
- Under no circumstances will a staff member use his/her personal vehicle to transport a client.
- Organization vehicles will be used only to carry out work-related duties. Vehicles are available primarily to facilitate the care of registered clients of [name of program]. However, it is recognized that the transport of a client’s nonregistered significant others is indicated at times and that the organization’s ability to provide transportation can also facilitate the process of engaging nonregistered individuals who might otherwise be reluctant to accept services. These circumstances will be viewed as exceptions and will be discussed and approved by the relevant team leader, program leader, project director, or his/her designee.
- The provision of transportation to clients and their significant others will be regarded as a service, and the staff members who transport these individuals will be expected to maintain the same professional standards of practice that guide the provision of all clinical services at [name of program]. Clients’ rights to safety and confidentiality will therefore be respected and protected at all times.
- Staff persons will carry an activated cellular phone when transporting clients.
- Organization vehicles used for client transport will be equipped with the following items for emergencies (e.g., accidental injuries, inclement weather):
  – An operable flashlight
  – Snow scraper
  – Personal protection gloves
  – First-aid kit
  – List of emergency phone numbers
  – Information regarding vehicle insurance coverage
  – Reflective safety triangles
- Staff will make a general inspection of the organization vehicle before driving it to make sure that there is adequate fuel and that there are no objects within or outside the vehicle that might compromise the safety of the driver or other vehicle occupants.
- The driver of any organization vehicle will maintain responsibility for ensuring that all vehicle occupants honor relevant seat-belt laws, including laws governing the use of child safety seats when applicable.
- The number of passengers transported in an organization vehicle will not exceed the vehicle’s stated capacity, and team-, program-, and project-identified staff-to-client ratios will be honored.
- Clients who are symptomatically unstable and whose behavior may be impulsive and/or unpredictable will not be transported in an organization vehicle, including clients suspected of being under the influence of any nonprescribed drug. Safety concerns that arise at any point during the course of transporting a client will result in termination of the transport.
- Clients will not be left unattended by the staff in an organization vehicle.
- Clients needing hospitalization will generally be transported via ambulance. Any exceptions will be reviewed and approved by the appropriate team leader, program leader, project director, or his/her designee and will be based on a thorough assessment of client needs and the availability of the resources necessary to facilitate safe transport. Factors that will preclude the transportation in a vehicle of a client needing hospitalization include, but are not limited to:
  – The presence of medical needs better addressed in an ambulance.
  – Client history of violence, impulsivity, substance use, or other factors that might contribute to unpredictability during transport.
  – The lack of at least two clinicians or case managers available to assist in the transport of the client.

### Management of Psychiatric and Medical Emergencies

#### Policy

Procedures will be established to guide the handling of psychiatric or medical emergencies within the office or in the community that require resources beyond the scope of [name of program] services. When a medical emergency occurs, basic life support, first aid, and immediate emergency care will be given until the arrival of emergency medical service (EMS) personnel, who will provide any further emergency treatment and transport to the emergency department (ED).

#### Purpose

To facilitate the safety of clients served by the [name of program] and the safety of team or project staff.

#### Procedures

Section A: Psychiatric/medical emergencies that occur within the office will be managed as follows:

- Staff members involved in the management of a psychiatric or medical emergency will dial 911 to access emergency services or will use the panic button system available within the office. If possible, one staff member will announce a Code 3 on the overhead telephone paging system, specify whether the code is medical, and note the location of the code.
- All available clinical staff persons will respond.
- The first senior staff member on the scene will take charge of a psychiatric code. The first senior medically trained staff member on the scene will take charge of a medical code. If the code bag and first-aid kits are not present, the staff member will direct another staff member to bring this equipment to the scene. If no medical personnel are available, the first person on the scene will be in charge of the code, direct basic support and first-aid to the victim, and designate someone to bring the code bag and first-aid kit.
- A staff member should gather relevant client data to provide to EMS and the ED. When EMS arrives, care of the victim in a medical code will be handed off to them. In the event of a psychiatric code, the staff member in charge of the code will manage the code collaboratively with EMS.
- The staff member in charge of the code will gather interim assistance from other staff working in the office at the time of the emergency. If the incident is in the office, a program supervisor will also facilitate the management of other clients who may be on site at the time of an emergency. These interventions will be guided by an appreciation of the importance of protecting all clients exposed to emergencies and of the need to preserve the rights, dignity, and well-being of all involved clients.
- The clinician and supervisor managing in-house psychiatric or medical emergencies are responsible for the completion of documentation needed to facilitate transport to an ED and will facilitate continuity of care for the client by communicating relevant information to ED care providers.
- After the care of the victim has been completely assumed by EMS, staff should:
  – Inform the client’s family or emergency contact persons.
  – Inform appropriate administrative staff persons.
  – Address and allay the anxiety of clients who witnessed the incident.
  – Meet to review the incident as soon as possible after it occurs.
- The involved clinician will complete an incident report and an emergency response form documenting the circumstances of the need for emergency services, and a review will be scheduled.
- A note will be entered into the medical record reflecting the circumstances of the emergency and the outcome of planned interventions.
- Following a medical code, the [position of person responsible] will direct a member of the nursing department to check the lock on the code bag. If the lock is broken, the nursing staff member will call [name, phone number] to check and replace contents.

Section B: Psychiatric or medical emergencies that occur in the community will be handled as follows:

- Staff members involved in handling a psychiatric or medical emergency in the community will use their cell phones to call the local police department directly or to call 911 to access emergency services. A call to 911 from a cell phone will access State Police, who will contact local police.
- A program supervisor will be notified of the emergency and will facilitate the deployment of additional staff resources as needed.
- A first-aid kit is kept in each vehicle to facilitate interim management of medical emergencies. No code bag is stored in vehicles.
- Documentation needed to facilitate transport to an ED will be completed by the clinician most involved in the emergency situation. The involved clinician will also give relevant client information to ED care providers to facilitate continuity of care.
- Procedures 3 through 9 as outlined in Section A of this policy will be followed.

## Sample Forms

Recordkeeping is a necessary part of engaging people who are homeless in services and tracking the course of these individuals’ contacts with service organizations. When possible, records should be kept electronically and updated as new information becomes available. Sample forms presented in the following pages include:

- Sample Memorandum of Understanding. MOUs document tasks and roles of partnership organizations.
- Sample Homelessness Outreach Contact Form. A sample of the type of form that can be used to document information gathered during early encounters between a service provider and a potential client. This sample form (along with the Sample Contact Log) is intended to be used during the outreach phase of homeless rehabilitation and illustrates the kinds of information you might want to record from outreach sessions. Although this form includes information that is useful, there is no expectation that it will be completed during the first several contacts with a potential client. Information gathering with people who have substance use disorders and are homeless is ongoing.
- Sample Contact Log. A sample of the type of form that can be used to capture case-finding work during outreach and engagement activities.
- Sample Case Management Discharge or Transfer Note. A sample of the type of form that is suited to record the circumstances of discharge or transfer.
- Sample Interagency Referral Form. A sample of the type of form that is designed to accompany an individual who is referred to an outside agency. It provides the information the client has disclosed that is relevant to the referral.

These documents are provided as a starting point for your organization. Each must be adapted to suit the particular philosophy and procedures of your organization.

Sample Memorandum of Understanding

Sample Homelessness Outreach Contact Form

Sample Contact Log

Sample Case Management Discharge or Transfer Note

Sample Interagency Referral Form