# An Implementation Guide for Behavioral Health Program Administrators

Part 2, Chapter 1

Part 2, Chapter 2