# A Practical Guide for the Provision of Behavioral Health Services

Part 1, Chapter 1

Part 1, Chapter 2