# Foreword

The Treatment Improvement Protocol (TIP) series fulfills the Substance Abuse and Mental Health Services Administration’s (SAMHSA’s) mission to improve prevention and treatment of substance use and mental disorders by providing best practices guidance to clinicians, program administrators, and payers. TIPs are the result of careful consideration of all relevant clinical and health services research findings, demonstration experience, and implementation requirements. A panel of non-Federal clinical researchers, clinicians, program administrators, and patient advocates debates and discusses their particular area of expertise until they reach a consensus on best practices. This panel’s work is then reviewed and critiqued by field reviewers.

The talent, dedication, and hard work that TIP panelists and reviewers bring to this highly participatory process have helped bridge the gap between the promise of research and the needs of practicing clinicians and administrators to serve, in the most scientifically sound and effective ways, people in need of behavioral health services. We are grateful to all who have joined with us to contribute to advances in the behavioral health field.

- Pamela S. Hyde, J.D.
  Administrator
  Substance Abuse and Mental Health Services Administration
- H. Westley Clark, M.D., J.D., M.P.H., CAS, FASAM
  Director
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
- Paolo del Vecchio, M.S.W.
  Director
  Center for Mental Health Services
  Substance Abuse and Mental Health Services Administration