# Consensus Panel

Consensus Panels Chair
- Hunter L. McQuistion, M.D.
  Director, Division of Outpatient & Community Psychiatry
  Department of Psychiatry and Behavioral Health
  The St. Luke’s and Roosevelt Hospitals
  Associate Clinical Professor of Psychiatry
  Columbia University College of Physicians & Surgeons
  New York, NY

Part 1 Consensus Panelists
- Jennifer Frey, Ph.D.
  KAP Expert Content Director
  The CDM Group, Inc.
  Bethesda, MD
- Eugene Medina
  Aurora, CO
- Jesse B. Milby, Jr., Ph.D.
  University of Alabama at Birmingham
  Department of Psychology
  Birmingham, AL
- Douglas J. Warn, LCSW-R
  Brooklyn, NY
- Tommy Wyatt
  Beliflower, CA

Part 2 Consensus Panelists
- Jennifer Frey, Ph.D.
  KAP Expert Content Director
  The CDM Group, Inc.
  Bethesda, MD
- Debbie Fisk, LCSW
  Director
  Outreach and Engagement Project
  New Haven, CT
- Kelvin M. Silver, M.Ed., LCPC, LCADC, CRC, NCC
  Baltimore, MD