# Acknowledgments

Numerous people contributed to the development of this Treatment Improvement Protocol (TIP), including the TIP Consensus Panel (see p. v), the Knowledge Application Program (KAP) Advisory Meeting Panel (Appendix B), the Stakeholders Meeting Participants (Appendix C), and the Field Reviewers (Appendix D).

This publication was produced under KAP, a Joint Venture of The CDM Group, Inc. (CDM), and JBS International, Inc. ( JBS), for the Substance Abuse and Mental Health Services Administration, Center for Substance Abuse Treatment.

CDM KAP personnel included Rose M. Urban, M.S.W., J.D., LCSW, LSAC, Executive Project Co-Director; Jessica Culotta, M.A., Managing Project Co-Director and former Managing Editor; Susan Kimner, former Managing Project Co-Director; Claudia Blackburn, Psy.D., Expert Content Director; Bruce Carruth, Ph.D., former Expert Content Director; Jennifer Frey, Ph.D., former Expert Content Director; Marilyn Kresky-Wolff, M.P.H., LCSW-C, former Administrative Content Director; Sheldon Weinberg, Ph.D., Senior Researcher/Applied Psychologist; Jonathan Max Gilbert, Ph.D., Writer/Editor; Leslie Kelley, former Writer/Editor; Angela Fiastro, Junior Editor; Virgie Paul, Librarian; and Maggie Nelson, former Project Coordinator.