# Field Reviewers

- Kanzoni Asabigi
  Deputy Director
  Substance Abuse Prevention, Treatment and Recovery
  Department of Health and Wellness Promotion
  Detroit, MI
- Kim M. Ball
  Clinical Supervision
  Montgomery County Department of Health and Human Services
  Silver Spring, MD
- Jessica Bass, CAC III, LCSW
  Team Leader
  Community Housing & Multi Cultural Services
  Arapahoe House, Inc.
  Lakewood, CO
- Hardy G. Bennett
  Manager III
  Montgomery County Department of Health and Human Services
  Rockville, MD
- Kathleen L. Estlund
  Star II Program Administrator
  Gateway Community Services, Inc.
  Jacksonville, FL
- Claude Grazia
  Supervising Clinician
  Substance Abuse Treatment Unit
  Connecticut Mental Health Center
  New Haven, CT
- Betty Kavanagh, LCSW-G
  Behavioral Health Officer
  Health Care for the Homeless, Inc.
  Baltimore, MD
- Stefan Kertesz, M.D.
  Assistant Professor
  Division of Preventive Medicine
  University of Alabama at Birmingham
  Birmingham, AL
- Donna LaPaglia, Psy.D.
  Associate Professor of Psychiatry
  Director of Substance Abuse Treatment Unit
  Yale University School of Medicine
  New Haven, CT
- ShunDell McGlothen
  Case Manager/Staff Advocate
  LAMP, Inc.
  Los Angeles, CA
- John Mitchell
  Littleton, CO
- Else Pedersen-Wasson, M.B.A., LAC
  Executive Director
  Bridge House Corporation
  New Orleans, LA
- Calvin R. Trent
  General Manager
  Special Populations Health Services
  Detroit Bureau of Substance Abuse Prevention, Treatment and Recovery
  Detroit, MI
- Sam Tsemberis
  Executive Director
  Pathways to Housing, Inc.
  New York, NY
- Nancy R. VanDeMark, M.S.W.
  Wheat Ridge, CO
- Carol Wilkins
  Director of Policy & Research
  Corporation for Supportive Housing
  Oakland, CA
- Darrell Woods
  Los Angeles, CA
- Renee Wyatt
  Money Management Coordinator
  LAMP, Inc.
  Los Angeles, CA
- Cynthia Zubritsky, Ph.D.
  Senior Research Faculty
  University of Pennsylvania Department of Psychiatry
  Philadelphia, PA