# Stakeholders Meeting Participants

- Michael Ahmadi
  Public Health Analyst
  Office of Communications
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Lynnette Araki, M.P.H.
  Senior Health Program Analyst
  Health Resources and Services Administration
  Rockville, MD
- Moe Armstrong, M.B.A., M.A.
  Director of Consumer and Family Affairs
  Vinfen Corporation
  Cambridge, MA
- Joseph H. Autry III, M.D.
  Senior Medical Associate & Interagency Coordinator
  Department of Veterans Affairs
  Washington, DC
- Christina Currier
  Contracting Officer’s Representative
  Knowledge Application Program
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Pete Dougherty
  Director
  Homeless Veterans Program (075D)
  Department of Veterans Affairs
  Washington, DC
- Janice Elliott
  Managing Director
  Corporation for Supportive Housing
  New Haven, CT
- Anne Fletcher, M.S.W., M.P.A.
  Social Science Analyst
  Office of the Assistant Secretary for Planning and Evaluation
  Department of Health and Human Services
  Washington, DC
- Joanne Gampel, M.A.
  Social Science Analyst
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Peggy Halpern
  Program Analyst
  Office of the Assistant Secretary for Planning and Evaluation
  U.S. Department of Health and Human Services
  Washington, DC
- Anne M. Herron, M.S.W.
  Director
  Division of State and Community Assistance
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Cynthia High
  Special Needs Assistance Program Specialist
  U.S. Department of Housing and Urban Development
  Washington, DC
- Jean Hochron
  Director
  Office of Minority and Special Populations
  Bureau of Primary Health Care
  Health Resources and Services Administration
  Rockville, MD
- Clarese V. Holden, Ph.D.
  Public Health Advisor
  Division of State Programs
  Center for Substance Abuse Prevention
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Mary Ellen Hombs
  Deputy Executive Director
  U.S. Interagency Council on Homelessness
  Washington, DC
- Richard Kopanda, M.A.
  Deputy Director
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Andrea Kopstein, Ph.D.
  Practice Improvement Branch Chief
  Division of Services Improvement
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Charlene LeFauve, Ph.D.
  Co-Occurring and Homeless Activities Branch Chief
  Division of State and Community Assistance
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Charlene Lewis, Ph.D.
  Public Health Analyst
  Office of the Administrator
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- John Lozier
  Executive Director
  National Health Care for the Homeless Council
  Nashville, TN
- Webb Lyons
  Assistant to the President
  National Alliance to End Homelessness
  Washington, DC
- Philip Mangano
  Executive Director
  U.S. Interagency Council on Homelessness
  Washington, DC
- Hunter L. McQuistion, M.D. (Chair)
  Director
  Division of Outpatient and Community Psychiatry
  Department of Psychiatry and Behavioral Health
  The St. Luke’s and Roosevelt Hospitals
  Associate Clinical Professor of Psychiatry
  Columbia University College of Physicians and Surgeons
  New York, NY
- Cheri Nolan
  Senior Advisor to the Administrator
  Office of the Administrator
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Cathy Nugent
  Public Health Advisor
  Division of Services Improvement
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Arne Owens, M.S.
  Senior Advisor to the Administrator
  Office of the Administrator
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Lawrence D. Rickards, Ph.D.
  Chief
  Homeless Programs Branch
  Center for Mental Health Services
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Lora Routt
  Director
  State Assistance Division Office of Special Needs Assistance Programs
  U.S. Department of Housing and Urban Development
  Washington, DC
- Ruth Samardick
  Director
  Homeless Assistance Programs
  Department of Labor
  Washington, DC
- Jack Stein, M.S.W., Ph.D.
  Director
  Division of Services Improvement
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Mark Weber
  Director
  Office of Communications
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Harry Wilson
  Associate Commissioner
  Family and Youth Services Bureau
  Administration for Children and Families
  U.S. Department of Health and Human Services
  Washington, DC