# Advisory Meeting Panel

- H. Westley Clark, M.D., J.D., M.P.H., CAS, FASAM
  Director
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Mady Chalk, Ph.D.
  Director
  Division of Services Improvement
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Christina Currier
  Public Health Analyst
  Practice Improvement Branch
  Division of Services Improvement
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Michael T. Flaherty, Ph.D.
  Northeast Addiction Technology Transfer Center
  Institute for Research, Education and Training in Addictions
  Pittsburgh, PA
- Kevin Hennessy, Ph.D.
  Science to Service Coordinator
  Office of Policy, Planning and Budget
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Constance M. Pechura, Ph.D.
  Senior Program Officer
  Robert Wood Johnson Foundation
  Princeton, New Jersey
- Richard A. Rawson, Ph.D.
  Pacific Southwest Addiction Technology Transfer Center
  Los Angeles, CA
- Jack B. Stein, Ph.D.
  Acting Deputy Director
  Division of Epidemiology, Services and Prevention Research
  National Institute on Drug Abuse
  National Institutes of Health
  Bethesda, MD
- Richard T. Suchinsky, M.D.
  Associate Chief for Addictive Disorders
  Mental Health and Behavioral Sciences Service
  U.S. Department of Veteran Affairs
  Washington, DC
- Karl D. White, Ed.D.
  Public Health Analyst
  Practice Improvement Branch
  Division of Services Improvement
  Center for Substance Abuse Treatment
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Mark Willenbring, M.D.
  Director
  Division of Treatment and Recovery Research
  National Institute on Alcohol Abuse and Alcoholism
  National Institutes of Health
  Bethesda, MD