# Bibliography

Addiction Technology Transfer Center Network. 2004. The change book: A blueprint for technology transfer. 2nd ed. Kansas City, MO. ATTC National Office.
Addiction Technology Transfer Center Network. 2004. The change book workbook: A companion to the change book: A blueprint for technology transfer. 2nd ed. Kansas City, MO. ATTC National Office.
American Association of Community Psychiatrists. 2002. AACP position statement: Representative payeeships, 2002. Dallas, TX. American Association of Community Psychiatrists.
American Psychiatric Association. 2000. Diagnostic and statistical manual of mental disorders. 4th ed. text rev. Washington, DC. American Psychiatric Association.
Arocena M. 2006. September. 2004–2005 statewide outcome evaluation report—Ad hoc report: Rainbow Days Curriculum-Based Support Group (CBSG) Program. Austin, TX. Texas Department of State Health Services.
Bassuk EL, Friedman SM. 2005. Facts on trauma and homeless children. Los Angeles. National Child Traumatic Stress Network.
Bernstein E, Topp D, Shaw E, Girard C, Pressman K, Woolcock E, et al. A preliminary report of knowledge translation: Lessons from taking screening and brief intervention techniques from the research setting into regional systems of care. Academic Emergency Medicine. 2009;16:1225-1233. [pmid: 20053242].
Bird CE, Jinnett KJ, Burnam MA, Koegel P, Sullivan G, Wenzel SL, et al. Predictors of contact with public service sectors among homeless adults with and without alcohol and other drug disorders. Journal of Studies on Alcohol. 2002;63:716-725. [pmid: 12529072].
Burt MR. 2001. What will it take to end homelessness?. Washington, DC. Urban Institute Press.
Burt MR, Aron LY, Douglas T, Valente J, Lee E, Iwen B. 1999. Homelessness: Programs and the people they serve. Washington, DC. Urban Institute Press.
Burt MR, Aron LY, Lee E, Valente J. 2001. Helping America’s homeless: Emergency shelter or affordable housing?. Washington, DC. Urban Institute Press.
Caton CLM, Wilkins C, Anderson J. 2007. People who experience long-term homelessness: Characteristics and interventions, Paper presented at the U.S. Department of Health and Human Services Toward Understanding Homelessness: The 2007 National Symposium on Homelessness.
Cattan M, Tilford S. 2006. Mental health promotion: A lifespan approach. Maidenhead, England. McGraw Hill/Open University Press.
Center for Mental Health Services. 2003. Blueprint for change: Ending chronic homelessness for persons with serious mental illnesses and co-occurring substance use disorders. HHS Publication No. (SMA) 04-3870. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1993. Improving treatment for drug-exposed infants. Treatment Improvement Protocol (TIP) Series 5. HHS Publication No. (SMA) 95-3057. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1993. Pregnant, substance-using women. Treatment Improvement Protocol (TIP) Series 2. HHS Publication No. (SMA) 93-1998. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1993. Screening for infectious diseases among substance abusers. Treatment Improvement Protocol (TIP) Series 6. HHS Publication No. (SMA) 953060. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1994. Simple screening instruments for outreach for alcohol and other drug abuse and infectious diseases. Treatment Improvement Protocol (TIP) Series 11. HHS Publication No. (SMA) 94-2094. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1995. Alcohol and other drug screening of hospitalized trauma patients. Treatment Improvement Protocol (TIP) Series 16. HHS Publication No.(SMA) 95-3041. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1995. Combining alcohol and other drug treatment with diversion for juveniles in the justice system. Treatment Improvement Protocol (TIP) Series 21. HHS Publication No. (SMA) 95-3051. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1995. Developing State outcomes monitoring systems for alcohol and other drug abuse treatment. Treatment Improvement Protocol (TIP) Series 14. HHS Publication No. (SMA) 95-3031. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1995. The role and current status of patient placement criteria in the treatment of substance use disorders. Treatment Improvement Protocol (TIP)Series 13. HHS Publication No. (SMA) 95-3021. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1995. The tuberculosis epidemic: Legal and ethical issues for alcohol and other drug abuse treatment providers. Treatment Improvement Protocol (TIP)Series 18. HHS Publication No. (SMA) 95-3047. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1996. Treatment drug courts: Integrating substance abuse treatment with legal case processing. Treatment Improvement Protocol (TIP) Series 23. HHS Publication No. (SMA) 96-3113. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1997. A guide to substance abuse services for primary care clinicians. Treatment Improvement Protocol (TIP) Series 24. HHS Publication No. (SMA) 97-3139. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1997. Substance abuse treatment and domestic violence. Treatment Improvement Protocol (TIP) Series 25. HHS Publication No. (SMA) 97-3163. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1998. Comprehensive case management for substance abuse treatment. Treatment Improvement Protocol (TIP) Series 27. HHS Publication No. (SMA) 98-3222. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1998. Continuity of offender treatment for substance use disorders from institution to community. Treatment Improvement Protocol (TIP) Series 30. HHS Publication No. (SMA) 98-3245. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1998. Naltrexone and alcoholism treatment. Treatment Improvement Protocol (TIP) Series 28. HHS Publication No. (SMA) 98-3206. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1998. Substance abuse among older adults. Treatment Improvement Protocol (TIP) Series 26. HHS Publication No. (SMA) 98-3179. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1998. Substance use disorder treatment for people with physical and cognitive disabilities. Treatment Improvement Protocol (TIP) Series 29. HHS Publication No. (SMA) 98-3249. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1999. Brief interventions and brief therapies for substance abuse. Treatment Improvement Protocol (TIP) Series 34. HHS Publication No. (SMA) 993353. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1999. Enhancing motivation for change in substance abuse treatment. Treatment Improvement Protocol (TIP) Series 35. HHS Publication No. (SMA) 99-3354. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1999. Screening and assessing adolescents for substance use disorders. Treatment Improvement Protocol (TIP) Series 31. HHS Publication No. (SMA) 99-3282. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1999. Treatment of adolescents with substance use disorders. Treatment Improvement Protocol (TIP) Series 32. HHS Publication No. (SMA) 99-3283. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1999. Treatment for stimulant use disorders. Treatment Improvement Protocol (TIP) Series 33. HHS Publication No. (SMA) 99-3296. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2000. Integrating substance abuse treatment and vocational services. Treatment Improvement Protocol (TIP) Series 38. HHS Publication No.(SMA) 00-3470. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2000. Substance abuse treatment for persons with child abuse and neglect issues. Treatment Improvement Protocol (TIP) Series 36. HHS Publication No. (SMA) 00-3357. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2000. Substance abuse treatment for persons with HIV/AIDS. Treatment Improvement Protocol (TIP) Series 37. HHS Publication No. (SMA) 00-3459. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2001. A provider’s introduction to substance abuse treatment for lesbian, gay, bisexual, and transgender individuals. HHS Publication No. (SMA) 01-3498. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2004. Clinical guidelines for the use of buprenorphine in the treatment of opioid addiction. Treatment Improvement Protocol (TIP) Series 40. HHS Publication No. (SMA) 04-3939. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2004. Substance abuse treatment and family therapy. Treatment Improvement Protocol (TIP) Series 39. HHS Publication No. (SMA) 04-3957. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2005. Medication-assisted treatment for opioid addiction. Treatment Improvement Protocol (TIP) Series 43. HHS Publication No. (SMA) 05-4048. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2005. Substance abuse treatment for adults in the criminal justice system. Treatment Improvement Protocol (TIP) Series 44. HHS Publication No.(SMA) 05-4056. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2005. Substance abuse treatment for persons with co-occurring disorders. Treatment Improvement Protocol (TIP) Series 42. HHS Publication No. (SMA) 05-3992. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2005. Substance abuse treatment: Group therapy. Treatment Improvement Protocol (TIP) Series 41. HHS Publication No. (SMA) 05-4056. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2006. Addiction counseling competencies: The knowledge, skills, and attitudes of professional practice. Technical Assistance Publication (TAP) Series 21. HHS Publication No. (SMA) 06-4171. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2006. Detoxification and substance abuse treatment. Treatment Improvement Protocol (TIP) Series 45. HHS Publication No. (SMA) 06-4131. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2006. Substance abuse: Administrative issues in intensive outpatient treatment. Treatment Improvement Protocol (TIP) Series 46. HHS Publication No. (SMA) 06-4151. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2006. Substance abuse: Clinical issues in intensive outpatient treatment. Treatment Improvement Protocol (TIP) Series 47. HHS Publication No. (SMA) 06-4182. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2008. Managing depressive symptoms in substance abuse clients during early recovery. Treatment Improvement Protocol (TIP) Series 48. HHS Publication No. (SMA) 08-4353. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2009. Addressing suicidal thoughts and behaviors in substance abuse treatment. Treatment Improvement Protocol (TIP) Series 50. HHS Publication No. (SMA) 09-4381. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2009. Clinical supervision and the professional development of the substance abuse counselor. Treatment Improvement Protocol (TIP) Series 52. HHS Publication No. (SMA) 09-4435. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2009. Incorporating alcohol pharmacotherapies into medical practice. Treatment Improvement Protocol (TIP) Series 49. HHS Publication No.(SMA) 09-4380. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2009. Substance abuse treatment: Addressing the specific needs of women. Treatment Improvement Protocol (TIP) Series 51. HHS Publication No.(SMA) 09-4426. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Christensen RC, Hodgkins CC, Garces LK, Estlund KL, Miller MD, Touchton R. Homeless, mentally ill and addicted: The need for abuse and trauma services. Journal of Health Care for the Poor and Underserved. 2005;16:615-622. [pmid: 16311487].
Connery L, Brekke J. A home-based family intervention for ethnic minorities with a mentally ill member. Conrad KJ, Matters MD, Hanrahan P, Luchins DJ, editors. Homelessness prevention in treatment of substance abuse and mental illness: Logic models and implementation of eight American projects. 1999:149-167. New York. Haworth Press.
Connors GJ, Donovan DM, DiClemente CC. 2001. Substance abuse treatment and the stages of change: Selecting and planning interventions. New York. Guilford Press.
Davidson L, Andres-Hyman R, Bedregal L, Tondora J, Fry J, Kirk TA. From double trouble to dual recovery: Integrating models of recovery in addiction and mental health. Journal of Dual Diagnosis. 2008;4:273-290.
Davidson L, White W. The concept of recovery as an organizing principle for integrating mental health and addiction services. The Journal of Behavioral Health Services & Research. 2007;34:109-120.
Dempster J, Gillig PM. Rural settings. Gillig PM, McQuistion HL, editors. Clinical guide to the treatment of the mentally ill homeless person. 2006:151-163. Washington, DC. American Psychiatric Publishing.
Draine J, Herman DB. Critical time intervention for reentry from prison for persons with mental illness. Psychiatric Services. 2007;58:1577-1581. [pmid: 18048559].
Englander-Golden P, Golden DE, Brookshire W, Snow CR, Haag MS, Chang ATS. Communication skills program for prevention of risky behaviors. Journal of Substance Use. 1996;1:38-46.
Eynan R, Langley J, Tolomiczenko G, Rhodes AE, Links P, Wasylenki D, et al. The association between homelessness and suicidal ideation and behaviors: Results of a cross-sectional survey. Suicide & Life-Threatening Behavior. 2002;32:418-427. [pmid: 12501966].
Fazel S, Khosla V, Doll H, Geddes J. The prevalence of mental disorders among the homeless in western countries: Systematic review and meta-regression analysis. PLoS Medicine. 2008;5:e225. [pmid: 19053169].
Fisk D, Sells D, Rowe M. Sober housing and motivational interviewing: The Treatment Access Project. Journal of Primary Prevention. 2007;28:281-293. [pmid: 17551837].
Forney JC, Lombardo S, Toro PA. Diagnostic and other correlates of HIV risk behaviors in a probability sample of homeless adults. Psychiatric Services. 2007;58:92-99. [pmid: 17215418].
French MT, McCollister KE, Sacks S, McKendrick K, De Leon G. Benefit-cost analysis of a modified therapeutic community for mentally ill chemical abusers. Evaluation and Program Planning. 2002;25:137-148.
Greenberg GA, Rosenheck RA. Correlates of past homelessness in the National Epidemiological Survey on Alcohol and Related Conditions. Administration and Policy in Mental Health. 2010;37:357-366. [pmid: 19763814].
Greenberg GA, Rosenheck RA. Mental health correlates of past homelessness in the National Comorbidity Study Replication. Journal of Health Care for the Poor and Underserved. 2010;21:1234-1249. [pmid: 21099075].
Hackman A, Dixon L. Assertive community treatment. Gillig PM, McQuistion HL, editors. Clinical guide to the treatment of the mentally ill homeless person. 2006:51-64. Washington, DC. American Psychiatric Publishing.
Hannigan T, Wagner S. 2003. Developing the “support” in supportive housing: A guide to providing services in housing. New York. Corporation for Supportive Housing.
Hart-Shagos E. 1999. Homelessness and its effects on children. Minneapolis, MN. Family Housing Fund.
Herman D, Conover S, Felix A, Nakagawa A, Mills D. Critical Time Intervention: an empirically supported model for preventing homelessness in high risk groups. Journal of Primary Prevention. 2007;28:295-312. [pmid: 17541827].
Institute of Medicine. 2009. Preventing mental, emotional, and behavioral disorders among young people: Progress and possibilities. Washington, DC. National Academies Press.
International Center for Clubhouse Development. 2009. How ICCD clubhouses can help. New York. International Center for Clubhouse Development.
Jainchill N, Hawke J, Yagelka J. Gender, psychopathology, and patterns of homelessness among clients in shelter-based TCs. American Journal of Drug and Alcohol Abuse. 2000;26:553-567. [pmid: 11097192].
Jones K, Colson PW, Holter MC, Valencia E, Wyatt RJ, Susser E, et al. Cost-effectiveness of Critical Time Intervention to reduce homelessness among persons with mental illness. Psychiatric Services. 2003;54:884-890. [pmid: 12773605].
Kertesz SG, Horton NJ, Friedmann PD, Saitz R, Samet JH. Slowing the revolving door: Stabilization programs reduce homeless persons’ substance use after detoxification. Journal of Substance Abuse Treatment. 2003;24:197-207. [pmid: 12810140].
Kertesz SG, Mullins AN, Schumacher JE, Wallace D, Kirk K, Milby JB. Long-term housing and work outcomes among treated cocaine-dependent homeless persons. Journal of Behavioral Health Services & Research. 2007;34:17-33. [pmid: 17171458].
King R, Jordan A, Mazurek E, Earle K, Earle E, Runham A. Assertive community treatment–co-dually diagnosed: The hyphen was the easy part. Mental Health Aspects of Developmental Disabilities. 2009;12:1-7.
Klinkenberg WD, Caslyn RJ, Morse GA, Yonker RD, McCudden S, Ketema F, et al. Prevalence of human immunodeficiency virus, hepatitis B, and hepatitis C among homeless persons with co-occurring severe mental illness and substance use disorders. Comprehensive Psychiatry. 2003;44:293-302. [pmid: 12923707].
Leginski W. Historical and contextual influences on the U.S. response to contemporary homelessness. Dennis D, Locke G, Khadduri J, editors. Toward understanding homelessness: The 2007 National Symposium on Homelessness Research. 2007:1-1-1-36. Washington, DC. U.S. Department of Health and Human Services.
Lester KM, Milby JB, Schumacher JE, Vuchinich R, Person S, Clay OJ. Impact of behavioral contingency management intervention on coping behaviors and PTSD symptom reduction in cocaine addicted homeless. Journal of Traumatic Stress. 2007;20:565-575. [pmid: 17721968].
The Lewin Group. 2004. Costs of serving homeless individuals in nine cities: Chart book. Falls Church, VA. The Lewin Group.
Lipman BJ. 2002. America’s working families and the housing landscape 1997–2001. Center for Housing Policy’s New Century Housing, 3. Washington, DC. National Housing Conference.
Macias C, Rodican CF, Hargreaves WA, Jones DR, Barreira PJ, Wang Q. Supported employment outcomes of a randomized controlled trial of ACT and clubhouse models. Psychiatric Services. 2006;57:1406-1415. [pmid: 17035557].
Madras BK, Compton WM, Avula D, Stegbauer T, Stein JB, Clark HW. Screening, brief interventions, referral to treatment (SBIRT) for illicit drug and alcohol use at multiple healthcare sites: Comparison at intake and 6 months later. Drug and Alcohol Dependence. 2009;99:280-295. [pmid: 18929451].
Magura S, Nwakeze PC, Rosenblum A, Joseph H. Substance misuse and related infectious diseases in a soup kitchen population. Substance Use & Misuse. 2000;35:551-583. [pmid: 10741541].
Mares AS, Rosenheck RA. Perceived relationship between military service and homelessness among homeless veterans with mental illness. Journal of Nervous and Mental Diseases. 2004;192:715-719.
Marlatt GA, Donovan DM. 2005. Relapse prevention: Maintenance strategies in the treatment of addictive behaviors. 2nd ed. New York, NY. Guilford Press.
McNamara C, Schumacher JE, Milby JB, Wallace D, Usdan S. Prevalence of nonpsychotic mental disorders does not affect treatment outcome in a homeless cocaine-dependent sample. American Journal of Drug and Alcohol Abuse. 2001;27:91-106. [pmid: 11373038].
McQuistion HL, Felix AD, Samuels J. 2008. Serving people with mental illness and homelessness. Tasman A, Kay J, Lieberman JA, editors. Psychiatry. 4th Edition. West Sussex, England. John Wiley and Sons.
McQuistion HL, Gillig PM. 2006. Mental illness and homelessness: An introduction. Gillig PM, McQuistion HL, editors. The American Association of Community Psychiatrists clinical guide to the treatment of the mentally ill homeless person. Washington, DC. American Psychiatric Press.
Milby JB, Schumacher JE, McNamara C, Wallace D, Usdan S. Initiating abstinence in cocaine abusing dually diagnosed homeless persons. Drug and Alcohol Dependence. 2000;60:55-67. [pmid: 10821990].
Milby JB, Schumacher JE, Raczynski JM, Caldwell E, Engle M, Michael M, et al. Sufficient conditions for effective treatment of substance abusing homeless persons. Drug and Alcohol Dependence. 1996;43:39-47. [pmid: 8957141].
Milby JB, Schumacher JE, Vuchinich RE, Freedman MJ, Kertesz S, Wallace D. Toward cost-effective initial care for substance-abusing homeless. Journal of Substance Abuse Treatment. 2008;34:180-191. [pmid: 17512156].
Milby JB, Schumacher JE, Wallace D, Freedman MJ, Vuchinich RE. To house or not to house: The effects of providing housing to homeless substance abusers in treatment. American Journal of Public Health. 2005;95:1259-1265. [pmid: 15983278].
Mueser KT, Meyer PS, Penn DL, Clancy R, Clancy DM, Salyers MP. The Illness Management and Recovery Program: Rationale, development, and preliminary findings. Schizophrenia Bulletin. 2006;32(S1):S32-S43. [pmid: 16899534].
National Alliance to End Homelessness. 2006. What Is Housing First?. Washington, DC. National Alliance to End Homelessness.
National Alliance to End Homelessness. 2010. Critical success factors in high performing rural continuums of care. Solutions Brief. March. 15. Washington, DC. National Alliance to End Homelessness.
National Center on Family Homelessness. 2011. State report card on child homelessness: America’s youngest outcasts 2010. Needham, MA. National Center on Family Homelessness.
Nelson G, Aubry T, Lafrance A. A review of the literature on the effectiveness of housing and support, assertive community treatment, and intensive case management interventions for persons with mental illness who have been homeless. American Journal of Orthopsychiatry. 2007;77:350-361. [pmid: 17696663].
Network for the Improvement of Addiction Treatment. 2008. A primer on process improvement. Madison, WI. Network for the Improvement of Addiction Treatment.
New York Presbyterian Hospital & Columbia University. 2011. The critical time intervention training manual. New York. New York Presbyterian Hospital & Columbia University.
North CS, Eyrich KM, Pollio DE, Spitznagel EL. Are rates of psychiatric disorders in the homeless population changing?. American Journal of Public Health. 2004;94:103-108. [pmid: 14713706].
O’Toole TP, Conde-Martel A, Gibbon JL, Hanusa BH, Freyder PJ, Fine MJ. Substance-abusing urban homeless in the late 1990s: How do they differ from nonsubstance- abusing homeless persons?. Journal of Urban Health. 2004;81:606-617. [pmid: 15466842].
Pearson CL, Locke G, Montgomery AE, Buron L, McDonald WR. 2007. The applicability of Housing First models to homeless persons with serious mental illness. Final report. Washington, DC. U.S. Department of Housing and Urban Development, Office of Policy Development and Research.
Prigerson HG, Desai RA, Mares WL, Rosenheck RA. Suicidal ideation and suicide attempts in homeless mentally ill persons: Age-specific risks of substance abuse. Social Psychiatry and Psychiatric Epidemiology. 2003;38:213-219. [pmid: 12664232].
Prochaska J, DiClemente C, Norcross J. In search of how people change: Applications to addictive behaviors. American Psychologist. 1992;47:1102-1114. [pmid: 1329589].
Putnam M, Shamseldin T, Rumpf B, Wertheimer D, Rio J. 2007. Developing community employment pathways for homeless job seekers in King County and Washington State: A report of the Taking Health Care Home Initiative. Washington, DC. The Corporation for Supportive Housing.
Robertson P, Myers DT. 2005. Digest of model programs for the homeless: Rural outreach and engagement and housing first. Glenside, PA. Pennsylvania Housing Choices.
Rosenheck R, Mares A. Implementation of supported employment for homeless veterans with psychiatric or addiction disorders: Two-year outcomes. Psychiatric Services. 2007;58:325-333. [pmid: 17325104].
Rowe M, Hoge M, Fisk D. Critical issues in serving people who are homeless and mentally ill. Administration and Policy in Mental Health and Mental Health Services Research. 1996;23:555-565.
Rowe M, Hoge MA, Fisk D. Services for mentally ill homeless persons: Street-level integration. American Journal of Orthopsychiatry. 1998;68:490-496. [pmid: 9686300].
Schanzer B, Dominguez B, Shrout PE, Caton CL. Homelessness, health status, and health care use. American Journal of Public Health. 2007;97:464-469. [pmid: 17267724].
Schonebaum AD, Boyd JK, Dudek KJ. A comparison of competitive employment outcomes for the clubhouse and PACT models. Psychiatric Services. 2006;57:1416-1420. [pmid: 17035558].
Sermons MW, Witte P. 2011. State of homelessness in America. Washington, DC. National Alliance to End Homelessness.
Shaheen G, Rio J. Recognizing work as a priority in preventing or ending homelessness. Journal of Primary Prevention. 2007;28:341-358. [pmid: 17564838].
Sosin MR, Bruni M, Reidy M. Paths and impacts in the progressive independence model: A homelessness and substance abuse intervention in Chicago. Journal of Addictive Diseases. 1995;14:1-20. [pmid: 8929930].
Spence S, Stevens R, Parks R. Cognitive dysfunction in homeless adults: A systematic review. Journal of the Royal Society of Medicine. 2004;97:375-379. [pmid: 15286189].
Stefancic A, Tsemberis S. Housing first for long-term shelter dwellers with psychiatric disabilities in a suburban county: A four-year study of housing access and retention. Journal of Primary Prevention. 2007;28:265-279. [pmid: 17592778].
Stein LI, Santos AB. 1998. Assertive community treatment of persons with severe mental illness. New York. W. W. Norton.
Substance Abuse and Mental Health Services Administration. n.d. About PATH. Rockville, MD. Substance Abuse and Mental Health Services Administration. Retrieved February 14, 2013, from: http://pathprogram.samhsa.gov/super/path/about.aspx.
Substance Abuse and Mental Health Services Administration. 2006. Transformation through partnerships: Systems change to end chronic homelessness (DVD). HHS Publication No. (SMA) 06-4172. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. 2009. Supported employment evidence-based practices (EBP) KIT. HHS Publication No. (SMA) 08-4364. Rockville, MD. Center for Mental Health Services, Substance Abuse and Mental Health Services Administration, U.S. Department of Health and Human Services.
Substance Abuse and Mental Health Services Administration. 2010. Permanent supportive housing evidence-based practices (EBP) KIT. HHS Publication No. (SMA) 10-4510. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. 2011. Addressing viral hepatitis in people with substance use disorders. Treatment Improvement Protocol (TIP) Series 53. HHS Publication No. (SMA) 11-4656. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. 2011. Leading change: A Plan for SAMHSA’s Roles and Actions 2011–2014. HHS Publication No. (SMA) 11-4629. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. 2011. Managing chronic pain in adults with or in recovery from substance use disorders. Treatment Improvement Protocol (TIP) Series 54. HHS Publication No. (SMA) 11-4661. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. 2013. Addressing the specific behavioral health needs of men. Treatment Improvement Protocol (TIP) Series 56. HHS Publication No. (SMA) 13-4736. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. planned a. Behavioral health services for American Indians and Alaska Natives. Treatment Improvement Protocol (TIP) Series. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. planned b. Building health, wellness, and quality of life for sustained recovery. Treatment Improvement Protocol (TIP) Series. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. planned c. Improving cultural competence. Treatment Improvement Protocol (TIP) Series. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. planned d. Managing anxiety symptoms in behavioral health services. Treatment Improvement Protocol (TIP) Series. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. planned e. Recovery in behavioral health services. Treatment Improvement Protocol (TIP) Series. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. planned f. Reintegration-related behavioral health issues in veterans and military families. Treatment Improvement Protocol (TIP) Series. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. planned g. Systems-level implementation of screening, brief intervention, and referral to treatment. Technical Assistance Publication (TAP) Series. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. planned h. Trauma-informed care in behavioral health services. Treatment Improvement Protocol (TIP) Series. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration. planned i. Using telephone- and Web-based technologies in behavioral health settings. Treatment Improvement Protocol (TIP) Series. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Substance Abuse and Mental Health Services Administration & Office of Applied Studies. Homeless admissions to substance abuse treatment: 2004. The DASIS Report. 2006;26:1-4.
Takach M, Buxbaum J. 2011. Developing federally qualified health centers into community networks to improve state primary care delivery systems. Washington, DC. National Academy for State Health Policy.
Townsend W, Boyd S, Griffin G, Hicks PL. 2000. Emerging best practices in mental health recovery. Columbus, OH. Ohio Department of Mental Health.
Tsemberis S, Gulcur L, Nakae M. Housing first, consumer choice, and harm reduction for homeless individuals with a dual diagnosis. American Journal of Public Health. 2004;94:651-656. [pmid: 15054020].
U.S. Department of Housing and Urban Development. 2001. Supportive housing program desk guide: Community planning and development. Washington, DC. U.S. Department of Housing and Urban Development.
U.S. Department of Housing and Urban Development. 2007. The annual homeless assessment report to Congress. Washington, DC. U.S. Department of Housing and Urban Development.
U.S. Department of Housing and Urban Development Office. 2007. The applicability of Housing First models to homeless persons with serious mental illness. Office of Policy Development and Research, U.S. Department of Housing and Urban Development.
U.S. Department of Housing and Urban Development. 2008. Supportive housing program desk guide. Washington, DC. Office of Community Planning and Development, U.S. Department of Housing and Urban Development.
U.S. Department of Housing and Urban Development. 2010. 2009 annual homeless assessment report (AHAR) to Congress. Washington, DC. U.S. Department of Housing and Urban Development.
U.S. Department of Housing and Urban Development. n.d. Housing choice vouchers fact sheet. Retrieved on February 20, 2013, from http://portal.hud.gov/hudportal/HUD?src=/topics/housing_choice_voucher_program_section_8.
U.S. Department of Housing and Urban Development, Office of Community Planning and Development. 2010. The 2009 annual homeless assessment report. Washington, DC. U.S. Department of Housing and Urban Development, Office of Community Planning and Development.
U.S. Department of Housing and Urban Development. 2011. The 2010 annual homeless assessment report to Congress. Washington, DC. U.S. Department of Housing and Urban Development.
U.S. Department of Housing and Urban Development & U.S. Department of Veterans Affairs. 2010. Veteran homelessness: A supplemental report to the 2009 annual homeless assessment report to Congress. Washington, DC. U.S. Department of Housing and Urban Development & U.S. Department of Veterans Affairs.
U.S. Interagency Council on Homelessness. 2011. Projects for the assistance in transition from homelessness (PATH). Washington, DC. United States Interagency Council on Homelessness.