# Consensus Panel

## Chair

Margaret Kotz, D.O.

Professor, Psychiatry and Anesthesiology

Case Western Reserve University School of Medicine

Director, Addiction Recovery Services

Case Medical Center

University Hospitals of Cleveland

Cleveland, Ohio

## Panelists

Michael Clark, M.D., M.P.H.

Associate Professor

Department of Psychiatry and Behavioral Sciences

Johns Hopkins University School of Medicine

Baltimore, Maryland

Peggy Compton, RN, Ph.D., FAAN

Associate Professor

UCLA School of Nursing

Los Angeles, California

Edward Covington, M.D.

Director, Neurological Center for Pain

Neurological Institute

Cleveland Clinic Foundation

Cleveland, Ohio

Carmen R. Green, M.D.

Associate Professor, Anesthesiology

Associate Professor, Health Management and Policy

Director, Health Disparities Research

Michigan Institute for Clinical and Health Research

Director, Pain Medicine Research

University of Michigan

Ann Arbor, Michigan

Joseph O. Merrill, M.D., M.P.H.

Clinical Assistant Professor of Medicine

University of Washington

Harborview Medical Center

Seattle, Washington

Steven D. Passik, Ph.D.

Associate Attending Psychologist

Department of Psychiatry and Behavioral Sciences

Memorial Sloan Kettering Cancer Center

Associate Professor of Psychiatry

Weill Medical College of Cornell

University Medical Center

New York, New York

Charles A. Simpson, D.C., DABCO

Vice President, Medical Director

The CHP Group

Beaverton, Oregon