# Acknowledgments

Numerous people contributed to the development of this TIP, including the TIP Consensus Panel (see p. ix) and TIP field reviewers (see Appendix E).

This publication was produced under the Knowledge Application Program (KAP), a Joint Venture of JBS International, Inc. ( JBS), and The CDM Group, Inc., and for the Substance Abuse and Mental Health Services Administration, Center for Substance Abuse Treatment.

Lynne MacArthur, M.A., A.M.L.S., served as the JBS KAP Executive Project Co-Director, and Barbara Fink, RN, M.P.H., served as the JBS KAP Managing Project Co-Director. Other JBS KAP personnel included Candace Baker, M.S.W., MAC, Deputy Director for Product Development; Kris Rusch, M.A., Senior Writer; Cathy Baker, M.Ed., Senior Writer; Martha Horn, Ph.D., Senior Writer; Frances Nebesky, M.A., Quality Assurance Editor; Wendy Caron, Quality Assurance Manager; Erin P. Doherty, Copy Editor; and Erin Sandor, Graphic Designer.