# Field Reviewers

Jane C. Ballantyne, M.D., FRCA

Professor, Anesthesiology and Critical Care

Penn Pain Medicine Center

Philadelphia, Pennsylvania

Declan T. Barry, Ph.D.

Associate Research Scientist

Yale University School of Medicine

New Haven, Connecticut

Sharon M. Freeman, Ph.D., M.S.N., PMHCNS-BC, CARN-AP

CEO

Center for Brief Therapy, P.C.

Fort Wayne, Indiana

Cynthia M. A. Geppert, M.D., Ph.D., M.P.H., FAPM, DAAPM

Chief

Consultation Psychiatry & Ethics

New Mexico Veterans Affairs Health Care System

Associate Professor of Psychiatry

Director of Ethics Education

University of New Mexico School of Medicine

Albuquerque, New Mexico

Patricia M. Good

Chief (retired)

Liaison and Policy Section

Office of Diversion Control

Drug Enforcement Administration

Arlington, Virginia

Douglas Gourlay, M.D., M.Sc., FRCP(C), FASAM

Director

Pain and Chemical Dependency Division

Wasser Pain Centre

Mount Sinai Hospital

Centre for Addiction and Mental Health

Toronto, Canada

Howard A. Heit, M.D., FACP, FASAM

Assistant Clinical Professor of Medicine

Georgetown School of Medicine

Fairfax, Virginia

Nathaniel Katz, M.D., M.S.

Adjunct Assistant Professor of Anesthesia

Tufts University School of Medicine

President & CEO

Analgesic Research

Needham, Massachusetts

Kenneth L. Kirsh, Ph.D.

Assistant Professor

Pharmacy Practice and Science

University of Kentucky

Lexington, Kentucky

Paul Kreis, M.D.

Professor, Medical Director

Division of Pain Medicine

University of California, Davis

Sacramento, California

Pamela A. Pavilonis, M.B.A., M.S., N.D.

Naturopathic Physician

West Linn, Oregon

Seddon R. Savage, M.D., M.S.

Director

Dartmouth Center on Addiction Recovery and Education

Hanover, New Hampshire

Pain Consultant

Manchester VA Medical Center

Manchester, New Hampshire

Randy Seewald, M.D.

Medical Director

Methadone Maintenance Treatment Program

Beth Israel Medical Center

New York, New York

Barbara St. Marie, ANP, GNP

Nurse Practitioner

Burnsville, Minnesota

Mark D. Sullivan, M.D., Ph.D.

Professor of Psychiatry and Behavioral Sciences

University of Washington

Seattle, Washington

Andrea Trescot, M.D.

Professor

Department of Anesthesia and Pain Medicine

Director

Pain Fellowship Program

University of Washington

Seattle, Washington

Norman Wetterau, M.D., FAAFM, FASAM

New York, New York

Penelope P. Ziegler, M.D., FASAM

Medical Director

Virginia Health Practitioners’ Monitoring Program

Richmond, Virginia