# Resources for Finding Complementary and Alternative Therapy Practitioners

Type of Therapy | Resource
Acupuncture | American Association of Acupuncture and Oriental Medicine (AAAOM) http://www.aaaomonline.org National Certification Commission for Acupuncture and Oriental Medicine (NCCAOM) http://www.nccaom.org
Biofeedback | Association for Applied Psychophysiology and Biofeedback http://www.resourcenter.net/Scripts/4Disapi9.dll/4DCGI/resctr/search.html
Chiropractic | American Chiropractic Association http://www.acatoday.org
Massage | American Massage Therapy Association http://www.amtamassage.org/findamassage/locator.aspx