# CFR Sample Consent Form and List of Personal Identifiers

Sample Consent Form

Individual Identifiers Under the Privacy Rule

The following 18 identifiers of a person or of relatives, employers, or household members of a person must be removed, and the covered entity must not have actual knowledge that the information could be used alone or in combination with other information to identify the individual, for the information to be considered de-identified and not protected health information (PHI):

- Names
- All geographic subdivisions smaller than a State, including county, city, street address, precinct, ZIP Code,^*^ and their equivalent geocodes
  * The first three digits of a ZIP Code are excluded from the PHI list if the geographic unit formed by combining all ZIP Codes with the same first three digits contains >20,000 people.
- All elements of dates (except year) directly related to an individual: all ages >89 and all elements of dates (including year) indicative of such age (except for an aggregate into a single category of age >90)
- Telephone numbers
- Fax numbers
- Email addresses
- Social Security numbers
- Medical record numbers
- Health-plan beneficiary numbers
- Account numbers
- Certificate and license numbers
- Vehicle identifiers and serial numbers, including license plate numbers
- Medical device identifiers and serial numbers
- Internet universal resource locators (URLs)
- Internet protocol (IP) addresses
- Biometric identifiers including fingerprints and voice prints
- Full-face photographic images and any comparable images
- Any other unique identifying number, characteristic, or code, except that covered identities may, under certain circumstances, assign a code or other means of record identification that allows de-identified information to be re-identified

Source: 45 CFR § 164.514 [b][2][i].