# Bibliography

Alford DP, Compton P, Samet JH. Acute pain management for patients receiving maintenance methadone or buprenorphine therapy. Annals of Internal Medicine. 2006;144(2):127-134. [pmid: 16418412].
American Academy of Pain Medicine, American Pain Society, & American Society of Addiction Medicine Committee on Pain and Addiction. 2001. Definitions related to the use of opioids for the treatment of pain (consensus statement). Retrieved February 10, 2011, from http://www.ampainsoc.org/advocacy/opioids2.htm.
American Psychiatric Association. 2000. Diagnostic and statistical manual of mental disorders. 4th ed. text revision. Washington, DC. Author.
American Psychiatric Association. 2006. American Psychiatric Association practice guidelines for the treatment of psychiatric disorders: Compendium. Arlington, VA. Author.
Angst MS, Clark DJ. Opioid-induced hyperalgesia: A qualitative systematic review. Anesthesiology. 2006;104:570-587. [pmid: 16508405].
Arnold RM, Han PK, Seltzer D. Opioid contracts in chronic nonmalignant pain management: Objectives and uncertainties. American Journal of Medicine. 2006;119(4):292-296. [pmid: 16564767].
Asghari A, Julaeiha S, Godarsi M. Disability and depression in patients with chronic pain: Pain or pain related beliefs?. Archives of Iranian Medicine. 2008;11(3):263-269. [pmid: 18426316].
Asmundson GJ, Coons MJ, Taylor S, Katz J. PTSD and the experience of pain: Research and clinical implications of Shared Vulnerability and Mutual Maintenance models. Canadian Journal of Psychiatry. 2002;47(10):930-937.
Ballantyne JC. Opioids for chronic nonterminal pain. Southern Medical Journal. 2006;99(11):1245-1255. [pmid: 17195420].
Ballas SK. Current issues in sickle cell pain and its management. Hematology. 2007:97-105. Retrieved February 10, 2011, from http://asheducationbook.hematologylibrary.org/cgi/content/full/2007/1/97. [pmid: 18024616].
Barry LC, Guo Z, Kerns RD, Duong BD, Reid MC. Functional self-efficacy and pain-related disability among older veterans with chronic pain in a primary care setting. Pain. 2003;104(1–2):131-137. [pmid: 12855322].
Bird J. Selection of pain measurement tools. Nursing Standard. 2003;18(13):33-39. [pmid: 14694870].
Braden JB, Sullilvan MD. Suicidal thoughts and behavior among adults with self-reported pain conditions in the National Comorbidity Survey Replication. Journal of Pain. 2008;9(12):1106-1115. [pmid: 19038772].
Breitbart W. Pain. O’Neill JF, Selwyn PA, Schietinger H, editors. A clinical guide to supportive and palliative care for HIV/AIDS. 2003:85-122. Rockville, MD. Health Resources and Services Administration. Retrieved February 10, 2011, from ftp://ftp.hrsa.gov//hab/pall/chap4.PDF.
Brookoff D. Chronic pain as a disease: The pathophysiology of disordered pain. McCarberg B, Passik SD, editors. Expert guide to pain management. 2005:1-33. Philadelphia. American College of Physicians.
Brox JI, Reikerås O, Nygaard Ø, Sørensen R, Indahl A, Holm I, et al. Lumbar instrumented fusion compared with cognitive intervention and exercises in patients with chronic back pain after previous surgery for disc herniation: A prospective randomized controlled study. Pain. 2006;122(1–2):145-155. [pmid: 16545523].
Brunton S. Approach to assessment and diagnosis of chronic pain. Journal of Family Practice. 2004;53(Suppl 10):S3-S10. [pmid: 15469763].
Burns TL, Ineck JR. Cannabinoid analgesia as a potential new therapeutic option in the treatment of chronic pain. Annals of Pharmacotherapy. 2006;40:251-260. [pmid: 16449552].
Butler SF, Budman SH, Fernandez KC, Houle B, Benoit C, Katz N, et al. Development and validation of the Current Opioid Misuse Measure. Pain. 2007;130:144-156. [pmid: 17493754].
Butler SF, Fernandez K, Benoit C, Budman SH, Jamison RN. Validation of the revised screener and opioid assessment for patients with pain. Journal of Pain. 2008;9:360-372. [pmid: 18203666].
Campbell JN, Meyer RA. Mechanisms of neuropathic pain. Neuron. 2006;52(1):77-92. Retrieved February 10, 2011, from http://www.pubmedcentral.nih.gov/articlerender.fcgi?tool=pubmed&pubmedid=17015228. [pmid: 17015228].
Cassano P, Fava M. Depression and public health: An overview. Journal of Psychosomatic Research. 2002;53(4):849-857. [pmid: 12377293].
Center for Substance Abuse Treatment. 1999. Brief interventions and brief therapies for substance abuse. Treatment Improvement Protocol 34. HHS Publication No. (SMA) 99–3353. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 1999. Enhancing motivation for change in substance abuse treatment. Treatment Improvement Protocol 35. HHS Publication No. (SMA) 99–3354. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2004. Clinical guidelines for the use of buprenorphine in the treatment of opioid addiction. Treatment Improvement Protocol 40. HHS Publication No. (SMA) 04–3939. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2005. Medication-assisted treatment for opioid addiction in opioid treatment programs. Treatment Improvement Protocol 43. HHS Publication No. (SMA) 05–4048. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2005. Substance abuse treatment for persons with co-occurring disorders. Treatment Improvement Protocol 42. HHS Publication No. (SMA) 05–3922. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2006. Detoxification and substance abuse treatment. Treatment Improvement Protocol 45. HHS Publication No. (SMA) 06–4131. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2007. National Summit on Recovery Conference report. September 28–29, 2005. HHS Publication No. (SMA) 07–4276. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. 2009. Addressing suicidal thoughts and behaviors in substance abuse treatment. Treatment Improvement Protocol 50. HHS Publication No. (SMA) 09–4381. Rockville, MD. Substance Abuse and Mental Health Services Administration.
Center for Substance Abuse Treatment. Emerging issues in the use of methadone. HHS Publication No. (SMA) 09-4368. Substance Abuse Treatment Advisory. 2009;8(1).
Chelminski PR, Ives TJ, Felix KM, Prakken SD, Miller TM, Perhac JS, et al. A primary care, multi-disciplinary disease management program for opioid-treated patients with chronic non-cancer pain and a high burden of psychiatric comorbidity. BMC Health Services Research. 2005;5(1):3. [pmid: 15649331].
Chou R, Fanciullo GJ, Fine PG, Adler JA, Ballantyne JC, Davies P, et al. for the American Pain Society–American Academy of Pain Medicine Opioids Guidelines Panel. Clinical guidelines. Journal of Pain. 2009;10(2):113-130. [pmid: 19187889].
Chou R, Fanciullo GJ, Fine PG, Miaskowski C, Passik SD, Portenoy RK. Opioids for chronic noncancer pain: Prediction and identification of aberrant drug-related behaviors—A review of the evidence for an American Pain Society and American Academy of Pain Medicine clinical practice guideline. Journal of Pain. 2009;10(2):131-146. [pmid: 19187890].
Ciccone DS, Just N, Bandilla EB, Reimer E, Ilbeigi MS, Wu W. Psychological correlates of opioid use in patients with chronic nonmalignant pain: A preliminary test of the downhill spiral hypothesis. Journal of Pain Symptom Management. 2000;20(3):180-192.
Collins ED, Kleber HD. Opioids: Detoxification. Galanter M, Kleber HD, editors. Textbook of substance abuse treatment. 2004:265-289. Arlington, VA. American Psychiatric Publishing.
Compton P, Gebhart GF. The neurophysiology of pain in addiction. Graham AS, Schultz TK, Mayo-Smith MF, Ries RK, Wilford BB, editors. Principles of addiction medicine. 3rd ed. 2003:901-917. Chevy Chase, MD. American Society of Addiction Medicine.
Cone EJ, Caplan YH. Urine toxicology testing in chronic pain management. Postgraduate Medicine. 2009;121(4):91-102. [pmid: 19641275].
Couto JE, Romney MC, Leider HL, Sharma S, Goldfarb NI. High rates of inappropriate drug use in the chronic pain population. Population Health Management. 2009;12(4):185-190. [pmid: 19663620].
Covington EC. Chronic pain management in spine disorders. Neurologic Clinics. 2007;25(2):539-566. [pmid: 17445743].
Covington EC. Pain and addictive disorder: Challenge and opportunity. Benzon HT, Rathmell JP, Wu CL, Turk DC, Argoff CE, editors. Raj’s practical management of pain. 4th ed. 2008:793-808. Philadelphia. Elsevier Mosby.
Daley DC, Marlatt GA, Spotts CE. Relapse prevention: Clinical models and intervention strategies. Graham AW, Schultz TK, Mayo-Smith MF, Ries RK, Wilford BB, editors. Principles of addiction medicine. 3rd ed. 2003:467-485. Chevy Chase, MD. American Society of Addiction Medicine.
Dennis ML, Foss MA, Scott CK. An eight-year perspective on the relationship between the duration of abstinence and other aspects of recovery. Evaluation Review. 2007;31(6):585-612. [pmid: 17986709].
Department of Veterans Affairs & Department of Defense. 2003. VHA pain outcomes toolkit. Washington, DC. Veterans Health Administration, U.S. Department of Defense.
Department of Veterans Affairs & Department of Defense, Management of Opioid Therapy for Chronic Pain Working Group. 2010. VA/DoD clinical practice guideline for management of opioid therapy for chronic pain. Washington, DC. Department of Veterans Affairs, U.S. Department of Defense.
Dersh J, Polatin PB, Gatchel RJ. Chronic pain and psychopathology: Research findings and theoretical considerations. Psychosomatic Medicine. 2002;64:773-786. [pmid: 12271108].
Devulder J, Jacobs A, Richarz U, Wiggett H. Impact of opioid rescue medication for breakthrough pain on the efficacy and tolerability of long-acting opioids in patients with chronic non-malignant pain. British Journal of Anaesthesia. 2009;103(4):576-585. [pmid: 19736216].
Dick BD, Rashtiq S. Disruption of attention and working memory traces in individuals with chronic pain. Anesthesia & Analgesia. 2007;104:1223-1229. [pmid: 17456678].
DuPen A, Shen D, Ersek M. Mechanisms of opioid-induced tolerance and hyperalgesia. Pain Management Nursing. 2007;8(3):113-121. [pmid: 17723928].
Edlund MJ, Sullivan M, Steffick D, Harris KM, Wells KB. Do users of regularly prescribed opioids have higher rates of substance use problems than nonusers?. Pain Medicine. 2007;8(8):647-656. [pmid: 18028043].
Edwards RR, Klick B, Buenaver L, Max MB, Haythornthwaite JA, Keller RB, et al. Symptoms of distress as prospective predictors of pain-related sciatica treatment outcomes. Pain. 2007;130(1–2):47-55. [pmid: 17156925].
Fishman S. 2007. Responsible opioid prescribing: A physician’s guide. Washington, DC. Waterford Life Sciences.
Fleming S, Rabago DP, Mundt MP, Fleming MF. CAM therapies among primary care patients using opioid therapy. BMC Complementary and Alternative Medicine. 2007;7:15. [pmid: 17506893].
Folstein MF, Folstein SE. 2010. Mini-Mental State Examination. 2nd ed. Lutz, FL. PAR, Inc.
Frank B, Serpell MG, Hughes J, Matthews JN, Kapur D. Comparison of analgesic effects and patient tolerability of nabilone and dihydrocodeine for chronic neuropathic pain: Randomised, crossover, double blind study. British Medical Journal. 2008;336(7637):199-201. [pmid: 18182416].
Gagnier JJ, van Tulder MW, Berman BM, Bombardier C. 2006. Herbal medicine for low back pain. Retrieved February 10, 2011, from http://www.cochrane.org/reviews/en/ab004504.html.
Gardner EL. What we have learned about addiction from animal models of drug self-administration. American Journal on Addictions. 2000;9(4):285-313. [pmid: 11155784].
Gaynes BN, Burns BJ, Tweed DL, Erickson P. Depression and health-related quality of life. Journal of Nervous and Mental Disease. 2002;190(12):799-806. [pmid: 12486367].
Gear RW, Miaskowski C, Heller PH, Paul SM, Gordon NC, Levine JD. Benzodiazepine mediated antagonism of opioid analgesia. Pain. 1997;71(1):25-29. [pmid: 9200170].
Geppert CM. To help and not to harm: Ethical issues in the treatment of chronic pain in patients with substance use disorders. Advances in Psychosomatic Medicine. 2004;25:151-171. [pmid: 15248373].
Glajchen M. Chronic pain: Treatment barriers and strategies for clinical practice. Journal of the American Board of Family Practice. 2001;14(3):211-218. [pmid: 11355054].
Gourlay DL, Heit HA. 2009. Compliance monitoring in chronic pain management. Ballantyne JC, Rathmell JP, Fishman SM, editors. Bonica’s management of pain. 4th ed. Baltimore. Lippincott Williams & Wilkins.
Gourlay DL, Heit HA, Almahrezi A. Universal precautions in pain medicine: A rational approach to the treatment of chronic pain. Pain Medicine. 2005;6(2):107-112. [pmid: 15773874].
Gourlay DL, Heit HA, Caplan Y. 2006. Urine drug testing in clinical practice. 3rd ed. San Francisco. California Academy of Family Physicians.
Green CR, Baker TA, Smith EM, Sato Y. The effect of race in older adults presenting for chronic pain management: A comparative study of black and white Americans. Journal of Pain. 2003;4(2):82-90. [pmid: 14622719].
Haefeli M, Elfering A. Pain assessment. European Spine Journal. 2006;15(Suppl 1):S17-S24. [pmid: 16320034].
Hart J. Complementary therapies for chronic pain management. Alternative and Complementary Therapies. 2008;14(2):64-68.
Hart RP, Martelli MF, Zasler ND. Chronic pain and neuropsychological functioning. Neuropsychology Review. 2000;10(3):131-149. [pmid: 10983898].
Hart RP, Wade JB, Martelli MF. Cognitive impairment in patients with chronic pain: The significance of stress. Current Pain and Headache Reports. 2003;7(2):116-126. [pmid: 12628053].
Heit HA. Creating and implementing opioid agreements. Disease Management Digest. 2003;7(1):2-3.
Heit HA, Covington E, Good PA. Dear DEA. Pain Medicine. 2004;5(3):303-308. [pmid: 15367311].
Heit HA, Gourlay DL. Urine drug testing in pain medicine. Journal of Pain and Symptom Management. 2004;27(3):260-267. [pmid: 15010104].
Heit HA, Gourlay DL. Buprenorphine: New tricks with an old molecule for pain management. Clinical Journal of Pain. 2008;24(2):93-97. [pmid: 18209513].
Hughes I, Kelly J, Kosky N, Lear G, Owens L, Ratcliffe J, et al. 2004. Clinical guidelines and evidence review for panic disorder and generalised anxiety disorder. Sheffield, UK. University of Sheffield. London. National Collaborating Centre for Primary Care.
Hurwitz EL, Carragee EJ, van der Velde G, Carroll LJ, Nordin M, Guzman J, et al. Treatment for neck pain: Noninvasive interventions. Journal of Manipulative and Physiological Therapeutics. 2008;33(45):S123-S152.
Institute for Clinical Systems Improvement. 2007. Assessment and management of chronic pain. 2nd ed. Bloomington, MN. Author.
International Association for the Study of Pain/Subcommittee on Taxonomy. Classification of chronic pain syndromes and definitions of pain terms. Pain. 1986;3(Suppl 3):S1-S226.
Jacobson PL, Mann JD. The valid informed consent-treatment contract in chronic non-cancer pain: Its role in reducing barriers to effective pain management. Comprehensive Therapy. 2004;30(2):101-104. [pmid: 15566105].
Kalso E, Edwards JE, Moore RA, McQuay HJ. Opioids in chronic non-cancer pain: Systematic review of efficacy and safety. Pain. 2004;112(3):372-398. [pmid: 15561393].
Karoly P, Ruehlman LS, Aiken LS, Todd M, Newton C. Evaluating chronic pain impact among patients in primary care: Further validation of a brief assessment instrument. Pain Medicine. 2006;7(4):289-298. [pmid: 16898938].
Katz NP, Fanciullo GJ. Role of urine toxicology testing in the management of chronic opioid therapy. Clinical Journal of Pain. 2002;18(Suppl 4):S76-S82. [pmid: 12479257].
Koob GF. Neurobiological substrates for the dark side of compulsivity in addiction. Neuropharmacology. 2009;56(Suppl 1):S18-S31.
Lebovits AH. Approaches to psychological assessment prior to multidisciplinary chronic pain management. Chronic pain management: Guidelines for multidisciplinary program development. 2000:173-187. New York. Informa.
Longo L, Parran T, Johnson B, Kinsey W. Addiction: Part II—Identification and management of the drug-seeking patient. American Family Physician. 2000;61(8):2401-2408. [pmid: 10794581].
Magill M, Ray LA. Cognitive-behavioral treatment with adult alcohol and illicit drug users: A meta-analysis of randomized controlled trials. Journal of Studies on Alcohol and Drugs. 2009;70(4):516-527. [pmid: 19515291].
Maheshwari AV, Boutary M, Yun AG, Sirianni LE, Dorr LD. Multimodal analgesia without routine parenteral narcotics for total hip arthroplasty. Clinical Orthopaedics and Related Research. 2006;453:231-238. [pmid: 17031312].
Manchikanti L, Giordano J, Boswell MV, Fellows B, Manchukonda R, Pampati V. Psychological factors as predictors of opioid abuse and illicit drug use in chronic pain patients. Journal of Opioid Management. 2007;3(2):89-100. [pmid: 17520988].
Mao J. Opioid-induced abnormal pain sensitivity: Implications in clinical opioid therapy. Pain. 2002;100:213-217. [pmid: 12467992].
McCabe SE, Cranford JA, Boyd CJ. The relationship between past-year drinking behaviors and nonmedical use of prescription drugs: Prevalence of co-occurrence in a national sample. Drug and Alcohol Dependence. 2006;1(3):281-288. [pmid: 16621337].
McCarberg W. A new class of analgesics: Cannabinoids (2 parts). Pain Medicine News. 2006;4(4).
McCracken LM, MacKichan F, Eccleston C. Contextual cognitive-behavioral therapy for severely disabled chronic pain sufferers: Effectiveness and clinically significant change. European Journal of Pain. 2007;11(3):314-322. [pmid: 16762571].
McCracken LM, Vowles VE, Eccleston C. Acceptance of chronic pain: Component analysis and a revised assessment method. Pain. 2004;107(1–2):159-166. [pmid: 14715402].
McEachrane-Gross F, Liebschutz JM, Berlowitz D. Use of selected complementary and alternative medicine (CAM) treatments in veterans with cancer or chronic pain: A cross-sectional survey. BMC Complementary and Alternative Medicine. 2006;6:34. [pmid: 17026768].
McMillin G, Urry F. 2007. Drug testing guide for chronic pain management services. Salt Lake City, UT. ARUP Laboratories.
Mehta V, Langford RM. Acute pain management for opioid dependent patients. Anaesthesia. 2006;61(3):269-276. [pmid: 16480353].
Mironer YE, Brown C, Satterthwaite J, Haasis J, LaTourette P. 2000. Relative misuse potential of different opioids: A large pain clinic experience. Atlanta, GA. American Pain Society.
Naliboff BD, Wu SM, Pham Q. Clinical considerations in the treatment of chronic pain with opiates. Journal of Clinical Psychology. 2006;62(11):1397-1408. [pmid: 16937352].
National Association of State Alcohol and Drug Abuse Directors. 2006. Current research on screening and brief intervention and implications for State alcohol and other drug (AOD) systems. Retrieved February 10, 2011, from: http://www.nasadad.org/resource.php?base_id=788.
National Center for Complementary and Alternative Medicine. 2007. What is Complementary and Alternative Medicine?. Retrieved February 10, 2011, from http://nccam.nih.gov/health/whatiscam.
National Center for Health Statistics. 2006. Health, United States, with chartbook on trends in the health of Americans. Washington, DC. U.S. Government Printing Office.
National Institute on Alcohol Abuse and Alcoholism. 2005. Helping patients who drink too much: A clinician’s guide. Bethesda, MD. Author. Retrieved February 10, 2011, from http://pubs.niaaa.nih.gov/publications/Practitioner/CliniciansGuide2005/clinicians_guide.htm.
National Institute on Drug Abuse. 2007. Drugs, brains, and behavior: The science of addiction. NIH Publication No. 07-5605. Bethesda, MD. Author. Retrieved February 10, 2011, from http://www.drugabuse.gov/scienceofaddiction.
National Institute on Drug Abuse. 2009. Principles of addiction treatment. NIH Publication No. 09-4180. Bethesda, MD. Author.
Nayak S, Matheis RJ, Agostinelli S, Shifleft SC. The use of complementary and alternative therapies for chronic pain following spinal cord injury: A pilot survey. Journal of Spinal Cord Medicine. 2001;24(1):54-62. [pmid: 11587436].
Nemmani KV, Mogil JS. Serotonin-GABA interactions in the modulation of mu- and kappa-opioid analgesia. Neuropharmacology. 2003;44(3):304-310. [pmid: 12604090].
Nestler EJ. The neurobiology of cocaine addiction. Science and Practice Perspectives. 2005;3(1):4-12. [pmid: 18552739].
Nicholson B, Passik SD. Management of chronic noncancer pain in the primary care setting. Southern Medicine Journal. 2007;100(10):1028-1036.
Noble M, Tregear SJ, Treadwell JR, Schoelles K. Long-term opioid therapy for chronic noncancer pain: A systematic review and meta-analysis of efficacy and safety. Journal of Pain Symptom Management. 2008;35(2):214-228.
Otis JD, Keane TM, Kerns RD. An examination of the relationship between chronic pain and post-traumatic stress disorder. Journal of Rehabilitation Research and Development. 2003;40(5):397-406. [pmid: 15080224].
Pakulska W, Czarnecka E. Effect of diazepam and midazolam on the antinociceptive effect of morphine, metamizol and indomethacin in mice. Pharmazie. 2001;56(1):89-91. [pmid: 11210678].
Passik SD, Kirsh KL. Opioid therapy in patients with a history of substance abuse. CNS Drugs. 2004;18(1):13-25. [pmid: 14731056].
Passik SD, Kirsh KL, Whitcomb L, Portenoy RK, Katz NP, Kleinman L, et al. A new tool to assess and document pain outcomes in chronic pain patients receiving opioid therapy. Clinical Therapeutics. 2004;26(4):552-561. [pmid: 15189752].
Peles E, Schreiber S, Gordon J, Adelson M. Significantly higher methadone dose for methadone maintenance treatment (MMT) patients with chronic pain. Pain. 2005;113:340-346. [pmid: 15661442].
Pence LB, Thorn BE, Jensen MP, Romano JM. Examination of perceived spouse responses to patient well and pain behavior in patients with headache. Clinical Journal of Pain. 2008;24(8):654-661. [pmid: 18806529].
Portenoy RK, Ugarte C, Fuller I, Haas G. Population-based survey of pain in the United States: Differences among White, African American, and Hispanic subjects. Journal of Pain. 2004;5(6):317-328. [pmid: 15336636].
Potter JS, Hennessy G, Borrow JA, Greenfield SF, Weiss RD. Substance use histories in patients seeking treatment for controlled-release oxycodone dependence. Drug and Alcohol Dependence. 2004;76(2):213-215. [pmid: 15488345].
Potter JS, Shiffman SJ, Weiss RD. Chronic pain severity in opioid-dependent patients. American Journal of Drug and Alcohol Abuse. 2008;34(1):101-107. [pmid: 18161648].
Quigley C. Opioid switching to improve pain relief and drug tolerability. Cochrane Database of Systematic Reviews. 2004;3:CD004847.
Ratcliffe GE, Enns MW, Belik S-L, Sareen J. Chronic pain conditions and suicidal ideation and suicide attempts: An epidemiologic perspective. Clinical Journal of Pain. 2008;24:204-210. [pmid: 18287825].
Reid MC, Engles-Horton LL, Weber MB, Kerns RD, Rogers EL, O’Connor PG. Use of opioid medications for chronic noncancer pain syndromes in primary care. Journal of General Internal Medicine. 2002;17(3):173-179. [pmid: 11929502].
Risdon A, Eccleston C, Crombez G, McCracken L. How can we learn to live with pain? A Q-methodological analysis of the diverse understandings of acceptance of chronic pain. Social Science and Medicine. 2003;56(2):375-386. [pmid: 12473322].
Rosenblum A, Joseph H, Fong C, Kipnis S, Cleland C, Portenoy R. Prevalence and characteristics of chronic pain among chemically dependent patients in methadone maintenance and residential treatment facilities. Journal of the American Medical Association. 2003;289(18):2370-2378. [pmid: 12746360].
Rupp T, Delaney KA. Inadequate analgesia in emergency medicine. Annals of Emergency Medicine. 2004;43(4):494-503. [pmid: 15039693].
Saffier K, Colombo C, Brown D, Mundt M, Fleming M. Addiction Severity Index in a chronic pain sample receiving opioid therapy. Journal of Substance Abuse Treatment. 2007;33:303-311. [pmid: 17376639].
Sanders SH, Harden RN, Vicente PJ. Evidence-based clinical practice guidelines for interdisciplinary rehabilitation of chronic nonmalignant pain syndrome patients. Pain Practice. 2005;5(4):303-315. [pmid: 17177763].
Satel SL, Kosten TR, Schuckit MA, Fischman MW. Should protracted withdrawal from drugs be included in DSM-IV?. American Journal of Psychiatry. 1993;150(5):695-704. [pmid: 8097618].
Savage SR. Assessment for addiction in pain-treatment settings. Clinical Journal of Pain. 2002;18(Suppl 4):S28-S38. [pmid: 12479252].
Savage SR, Joranson DE, Covington EC, Schnoll SH, Heit HA, Gilson AM. Definitions related to the medical use of opioids. Journal of Pain and Symptom Management. 2003;26(1):655-667. [pmid: 12850648].
Savage SR, Kirsh KL, Passik SD. Challenges in using opioids to treat pain in persons with substance use disorders. Addiction Science and Clinical Practice. 2008;4(2):4-25. [pmid: 18497713].
Schillinger D, Piette J, Grumbach K, Wang F, Wilson C, Daher C, et al. Closing the loop: Physician communication with diabetic patients who have low health literacy. Archives of Internal Medicine. 2003;163(1):83-90. [pmid: 12523921].
Scott KM, Hwang I, Chiu W-T, Kessler RC, Sampson NA, Angermeyer M, et al. Chronic physical conditions and their association with first onset of suicidal behavior in the World Mental Health Surveys. Psychosomatic Medicine. 2010;72:712-719. [pmid: 20498290].
Sheu R, Lussier D, Rosenblum A, Fong C, Portenoy J, Joseph H, et al. Prevalence and characteristics of chronic pain in patients admitted to an outpatient drug and alcohol treatment program. Pain Medicine. 2008;9(7):911-917. [pmid: 18346064].
Simpson CA. Complementary medicine in chronic pain treatment. Physical Medicine and Rehabilitation Clinics of North America. 2006;17(2):451-472. [pmid: 16616277].
Sloman R, Rosen G, Rom M, Shir Y. Nurses’ assessment of pain in surgical patients. Journal of Advanced Nursing. 2005;52(2):125-132. [pmid: 16164473].
Stalnikowicz R, Mahamid R, Kaspi S, Brezis M. Undertreatment of acute pain in the emergency department: A challenge. International Journal for Quality in Health Care. 2005;17(2):173-176. [pmid: 15723816].
Substance Abuse and Mental Health Services Administration. 2007. Results from the 2006 National Survey on Drug Use and Health: National findings. NSDUH Series H-32. HHS Publication No. (SMA) 07-4293. Rockville, MD. Author.
Substance Abuse and Mental Health Services Administration. 2008. Results from the 2007 National Survey on Drug Use and Health: National findings. NSDUH Series H-34. HHS Publication No. (SMA) 08-43433. Rockville, MD. Author.
Sullivan M, Ferrell B. Ethical challenges in the management of chronic nonmalignant pain: Negotiating through the cloud of doubt. Journal of Pain. 2005;6(1):2-9. [pmid: 15629412].
Tang NK, Crane C. Suicidality in chronic pain: A review of the prevalence, risk factors and psychological links. Psychological Medicine. 2006;36:575-586. [pmid: 16420727].
Thorn BE, Pence LB, Ward LC, Kilgo G, Clements KL, Cross TH, et al. A randomized clinical trial of targeted cognitive behavioral treatment to reduce catastrophizing in chronic headache sufferers. Journal of Pain. 2007;8(12):938-949. [pmid: 17690017].
Trafton J, Oliva EM, Horst DA, Minkel JD, Humphreys K. Treatment needs associated with pain in substance use disorder patients: Implications for concurrent treatment. Drug and Alcohol Dependence. 2004;73:23-31. [pmid: 14687956].
Trescot AM, Datta S, Lee M, Hansen H. Opioid pharmacology. Pain Physician. 2008;11:S133-S153. [pmid: 18443637].
Turner J, Mancl L, Aaron L. Short- and long-term efficacy of brief cognitive-behavioral therapy for patients with chronic temporomandibular disorder pain: A randomized, controlled trial. Pain. 2006;121:181-194. [pmid: 16495014].
U.S. Commission on the Evaluation of Pain. 1987. Appendix C: Summary of the National Study of Chronic Pain Syndrome. Report of the Commission on the Evaluation of Pain. Washington, DC. U.S. Government Printing Office.
U.S. Department of Health and Human Services. 2000. Healthy people 2010: Understanding and improving health. Stock No. 017-001-001-00-550-9. Washington, DC. U.S. Government Printing Office.
U.S. Food and Drug Administration. 2006. FDA Public Health Advisory: Combined Use of 5-Hydroxytriptamine Receptor Agonists (Triptans), Selective Serotonin Reuptake Inhibitors (SSRIs) or Selective Serotonin/Norepinenphrine Reuptake Inhibitors (SNRIs) May Result in Life-Threatening Serotonin Syndrome. Rockville, MD. Center for Drug Evaluation and Research.
Vaillant GE. Natural history of addiction and pathways to recovery. Graham AW, Schultz TK, Mayo-Smith MF, Ries RK, Wilford BB, editors. Principles of addiction medicine. 3rd ed. 2003:3-16. Chevy Chase, MD. American Society of Addiction Medicine.
Van Ameringen M, Mancini C, Pipe B, Bennett M. Antiepileptic drugs in the treatment of anxiety disorders: Role in therapy. Drugs. 2004;64(19):2199-2220. [pmid: 15456335].
Vernon H, Humphreys K, Hagino C. Chronic mechanical neck pain in adults treated by manual therapy: A systematic review of change scores in randomized clinical trials. Journal of Manipulative and Physiological Therapeutics. 2007;30(3):215-227. [pmid: 17416276].
Vitiello MV, Rybarczyk B, Von Korff M, Stepanski EJ. Cognitive behavioral therapy for insomnia improves sleep and decreases pain in older adults with co-morbid insomnia and osteoarthritis. Journal of Clinical Sleep Medicine. 2009;5(4):355-362. [pmid: 19968014].
Volkow ND, Li T. Drug addiction: The neurobiology of behavior gone awry. Ries R, Fiellin D, Miller S, Saitz R, editors. Principles of addiction medicine. 4th ed. 2009:3-12. Philadelphia, PA. Lippincott Williams & Wilkins.
Wang J, Christo PJ. The influence of prescription monitoring programs on chronic pain management. Pain Physician. 2009;12(3):507-515. [pmid: 19461820].
Wasan AD, Butler SF, Budman SH, Benoit C, Fernandez K, Jamison RN. Psychiatric history and psychologic adjustment as risk factors for aberrant drug-related behavior among patients with chronic pain. Clinical Journal of Pain. 2007;23(4):307-315. [pmid: 17449991].
Weaver M, Schnoll S. Addiction issues in prescribing opioids for chronic nonmalignant pain. Journal of Addiction Medicine. 2007;1(1):2-10. [pmid: 21768925].
Webster LR, Webster RM. Predicting aberrant behaviors in opioid-treated patients: Preliminary validation of the Opioid Risk Tool. Pain Medicine. 2005;6(6):432-442. [pmid: 16336480].
Weinstock J, Barry D, Petry NM. Exercise-related activities are associated with positive outcome in contingency management treatment for substance use disorders. Addictive Behaviors. 2008;33(8):1072-1075. [pmid: 18486352].
Weissman DE, Haddox JD. Opioid pseudo-addiction—An iatrogenic syndrome. Pain. 1989;36(3):363-366. [pmid: 2710565].
Weschules DJ, Baib KT, Richeimer S. Actual and potential drug interactions associated with methadone. Pain Medicine. 2008;9(30):315-344. [pmid: 18386306].
Williams LS, Jones WJ, Shen J, Robinson RL, Kroenke K. Outcomes of newly referred neurology outpatients with depression and pain. Neurology. 2004;63(4):674-677. [pmid: 15326241].
Wu SM, Compton P, Bolus R, Schieffer B, Pham Q, Baria A, et al. The Addiction Behaviors Checklist: Validation of a new clinician-based measure of inappropriate opioid use in chronic pain. Journal of Pain and Symptom Management. 2006;32(4):342-351. [pmid: 17000351].
Ziegler P. 2007. Treating chronic pain in the shadow of addiction. Retrieved February 10, 2011, from http://www.emergingsolutionsinpain.com/index.php?option=com_continued&cat=20&Itemid=267.