# Consensus Panel

## Chair

David A. Fiellin, M.D.

Professor of Medicine and of Public Health and Associate Professor of Investigative Medicine

Yale University School of Medicine

New Haven, Connecticut

## Panelists

Valentin Bonilla, Jr., RPA

Chief Physician Assistant

Methadone Maintenance Medical Center

Beth Israel Medical Center

New York, New York

Danielle Brown, M.P.H.

Clinical Research Supervisor

Mt. Sinai Medical Center

Mount Vernon, New York

Bruce Burkett

Executive Director

Missouri Hepatitis C Alliance

Columbia, Missouri

Eugenia Curet, M.S.W., Ph.D.

Clinical Instructor in Public Health

Administrative Director

Adult and Adolescent Services Clinics

Cornell Weill Medical College

New York, New York

Brian R. Edlin, M.D.

Associate Professor of Medicine and Public Health

Center for the Study of Hepatitis C

Cornell Weill Medical College

New York, New York

William James Harrison III, M.H.S., CADC

Site Director

Brandywine Counseling, Inc.

Wilmington, Delaware

Alain Litwin, M.D., M.P.H.

Division of Internal Medicine

Montefiore Medical Center

Bronx, New York

Susan Simon

President and Founder

Hepatitis C Association

Scotch Plains, New Jersey

Shiela M. Strauss, Ph.D.

Associate Professor

Director

Muriel and Virginia Pless Center for Nursing Research

New York University College of Nursing

New York, New York

Theodore Paul Ziegler

Chief Executive Officer

Community Health Center

Akron, Ohio