# What Is a TIP?

Treatment Improvement Protocols (TIPs) are developed by the Center for Substance Abuse Treatment (CSAT), part of the Substance Abuse and Mental Health Services Administration (SAMHSA) within the U.S. Department of Health and Human Services (HHS). Each TIP involves the development of topic-specific best-practice guidelines for the prevention and treatment of substance use and mental disorders. TIPs draw on the experience and knowledge of clinical, research, and administrative experts of various forms of treatment and prevention. TIPs are distributed to facilities and individuals across the country. Published TIPs can be accessed via the Internet at http://www.kap.samhsa.gov.

Although each consensus-based TIP strives to include an evidence base for the practices it recommends, SAMHSA recognizes that behavioral health is continually evolving, and research frequently lags behind the innovations pioneered in the field. A major goal of each TIP is to convey “front-line” information quickly but responsibly. If research supports a particular approach, citations are provided.

## TIP Format

This TIP is organized into two parts:

- Part 1 is for counselors and administrators of behavioral health programs providing substance abuse treatment. It comprises seven chapters and emphasizes steps substance abuse treatment counselors and administrators can take to educate clients, prevent new hepatitis infections, and help clients who have viral hepatitis recover from their substance use disorders (SUDs). Information is provided at a basic level so that it can be understood by readers without medical training. Chapter 1 presents an overview of the most common types of viral hepatitis. Chapters 2 and 3 provide detailed information on screening for hepatitis and evaluation, respectively. Factors to consider when helping a client decide whether to undergo hepatitis treatment are addressed in Chapter 4; the treatment process is explained in Chapter 5. Chapter 6 describes counseling approaches for treating clients who have SUDs and viral hepatitis. Chapter 7 offers recommendations for administrators on how to add or improve hepatitis services, showcasing programs with proven track records. Note: Many people in treatment for SUDs are affected by mental disorders prior to the start of hepatitis treatment; mental disorders also may arise through the course of hepatitis treatment. Guidance for addressing co-occurring mental disorders is included throughout the TIP. Hepatitis-related issues specific to the treatment of mental disorders, not in the context of co-occurring SUDs, are covered in Appendix F.
- Part 2 is an online literature review for clinical supervisors, program administrators, and counselors interested in reviewing the medical literature on which this TIP is based. The literature review, available at http://www.kap.samhsa.gov, will be updated every 6 months for 5 years following publication of this TIP.

## TIP Development Process

TIP topics are based on the current needs of behavioral health professionals and other healthcare providers for information and guidance. After selecting a topic, SAMHSA invites staff members from Federal agencies and national organizations to be members of a resource panel that reviews an initial draft prospectus and outline and recommends specific areas of focus, as well as resources that should be considered in developing the content for the TIP. These recommendations are communicated to a consensus panel composed of experts on the topic who have been nominated by their peers. In partnership with Knowledge Application Program writers, consensus panel members participate in creating a draft document and then meet to review and discuss the draft. The information and recommendations on which they reach consensus form the foundation of the TIP. A panel chair ensures that the guidelines mirror the results of the group’s collaboration.

A diverse group of experts closely reviews the draft document. Once the changes recommended by these field reviewers have been incorporated, the TIP is prepared for publication, in print and online. TIPs can be accessed via the Internet at http://www.kap.samhsa.gov.