# Adding or Improving Hepatitis Services: A Guide for Administrators

## Program Assessment and Planning

A significant positive correlation has been found between administrators’ beliefs about the value of hepatitis services and the availability of hepatitis-related services at their substance abuse treatment programs (Astone, Strauss, Hagan, & Des Jarlais, 2004). To determine the types of services to implement or enhance treatment, administrators must consider the client population, staffing patterns and issues, availability of local resources, potential partners, and sources of funding. Program administrators can support the provision of hepatitis services by allocating a budget for implementation and by training or hiring appropriate staff members to implement the new services.

Hepatitis services include the following:

- Screening for viral hepatitis
- Medical evaluation and diagnosis
- Treatment for chronic hepatitis
- Prevention and vaccination
- Education
- Support services
- Outreach

A first step toward implementing change is to assess the hepatitis services currently offered by the substance abuse treatment program and identify components that could be implemented or expanded. This assessment can be performed by a workgroup or task force consisting of staff members interested in implementing or expanding hepatitis services. A group comprising staff members from different disciplines can provide diverse information and viewpoints. The next step is to consider the staff at hand, possible funding sources, and local agencies that could partner with the treatment program to provide hepatitis services.

Once these steps are completed, an implementation plan should be written. Organizational change might be needed to develop and sustain hepatitis treatment services. Technical Assistance Publication (TAP) 31, Implementing Change in Substance Abuse Treatment Programs (Center for Substance Abuse Treatment [CSAT], 2009a), provides practical advice regarding this topic and about incorporating new components into a treatment program.

## Screening for Viral Hepatitis

Screening activities include:

- Assessing a client’s risks of acquiring or transmitting hepatitis.
- Obtaining a client’s history of hepatitis infection or vaccination.
- Conducting blood tests for hepatitis or working with local health departments and other medical facilities that provide screening tests.

Because drug use is a risk factor for contracting viral hepatitis, the Centers for Disease Control and Prevention recommends that all clients in substance abuse treatment programs have routine access to hepatitis screening services. Clients who use or have used injection drugs are at particular risk of contracting viral hepatitis. (Chapters 1 and 2 provide information on risk factors and screening, respectively.) Substance abuse treatment programs can screen for viral hepatitis during the intake medical examination (Hagan, Strauss, Astone, & Des Jarlais, 2005). Treatment Improvement Protocol (TIP) 40, Clinical Guidelines for the Use of Buprenorphine in the Treatment of Opioid Addiction (CSAT, 2004); and TIP 43, Medication-Assisted Treatment for Opioid Addiction in Opioid Treatment Programs (CSAT, 2005), provide information about screening and assessing clients.

Most opioid treatment programs (OTPs) have onsite medical staff members who can draw blood samples for hepatitis screening tests. With the client’s consent, an OTP that routinely provides physical examinations could add a hepatitis test to a client’s initial blood work. Because viral hepatitis is a communicable disease, new cases must be reported. In many cases, the laboratory reports the case, but program administrators should contact local or State health departments for current information about reporting requirements and procedures; this information should be included in the program’s written procedures.

## Medical Evaluation and Diagnosis

Evaluation and diagnosis activities include providing onsite medical evaluations after a screening, or referring clients to local providers for evaluation and diagnosis.

The medical screening and evaluation of hepatitis B and C can be complicated, and the required laboratory tests are expensive. However, a qualified and experienced medical care provider can order proper tests, evaluate the results, provide an accurate diagnosis, and make treatment recommendations. Evaluative services are needed after a positive test result for hepatitis B and C. The Institute of Medicine (2010) recommends that the inability of a facility to provide evaluation and diagnosis services should not be an impediment to its providing screening services.

## Treatment for Chronic Hepatitis

Hepatitis treatment activities include providing treatment onsite at the substance abuse treatment program or referring clients to local partners, establishing a multidisciplinary treatment team, and obtaining clients’ permission to share information among team members. Substance abuse treatment program administrators tend to agree that hepatitis treatment for clients in recovery from substance use disorders (SUDs) is important. However, opinions diverge on when and how to treat clients for chronic hepatitis while they are in early recovery (Strauss, Astone, Hagan, & Des Jarlais, 2004). Some administrators are reluctant to refer clients for hepatitis treatment, citing difficult treatment regimens and serious side effects that could jeopardize a client’s recovery. Research suggests, however, that people in recovery from substance abuse can successfully adhere to the prescribed course of antiviral medication. Some clients will need financial assistance for hepatitis treatment. Low- and no-cost healthcare sources are listed in Appendix H.

Case Study: Funding Comprehensive Services, Project Samaritan Health Services, New York City

Project Samaritan Health Services provides hepatitis C care at four residential treatment facilities and a community-based facility in the New York City area. The program was established in response to State recommendations that substance abuse treatment centers provide hepatitis screening and education to clients—a recommendation the program fully supported. Project Samaritan administrators also wanted to help all clients with hepatitis obtain proper treatment. Project Samaritan provides education and training to its counselors and medical health care personnel so that they are well versed in working with clients who have hepatitis.

More than 25 percent of Project Samaritan’s clients do not have medical insurance. By forming a coalition of several large substance abuse treatment programs in New York State that collectively serve approximately 10,000 clients, Project Samaritan and its partners persuaded State officials to expand Medicaid to cover hepatitis-associated services, including testing for hepatitis C. The coalition also persuaded the State to convene a workgroup that created comprehensive guidelines for hepatitis care. Administrators worked with compassionate care programs to provide medications to eligible individuals; they also worked with a national medical laboratory to provide laboratory testing at no charge for individuals with incomes below the poverty level, and they negotiated with a local hospital to provide a substantially discounted rate for liver biopsy procedures.

Other hepatitis services are provided by Project Samaritan’s medical staff. Physicians specializing in gastroenterology or hepatology provide hepatitis treatment. A nurse practitioner works approximately 8 hours per week; a physician, approximately 12 hours.

Despite a rigorous treatment regimen and limited hours dedicated to providing hepatitis care, Project Samaritan has a low rate of attrition. The program’s hepatologist attributes the low dropout rate, in large part, to two factors: (1) extensive education offered to patients about treatment and its implications; and (2) patient empowerment to make decisions about their treatment. The program works to be client centered and strives to positively engage clients in treatment by emphasizing the steps that clients can take to improve their health.

Interviews by a JBS International, Inc., consultant with Administrators Marguerite Gebhardt and Pat Kennedy on April 22, 2008, and with hepatologist Nicholas Triantafillou, M.D., on April 23, 2008.

### Onsite Treatment

Onsite medical care in substance abuse treatment programs has been shown to be more effective than outside referrals for improving clients’ overall health and their access to comprehensive medical care (Samet, Saitz, & Larsen, 1996; Umbricht-Schneiter, Ginn, Pabst, & Bigelow, 1994). Advantages of providing onsite medical care include the ability to address both needs in one visit and streamlined communication between substance abuse treatment counselors and medical care providers (Sorensen, Masson, & Perlman, 2002). Onsite medical care providers learn more about clients’ substance use behaviors and can monitor and manage psychiatric disorders (Vassilev, Strauss, Astone, Friedmann, & Des Jarlais, 2004), which might encourage adherence to treatment. Communication among counseling and medical staff members about a client’s hepatitis status, while maintaining appropriate client confidentiality, can improve client care. Administrators should keep abreast of guidelines about hepatitis treatment eligibility (Exhibit 7-1).

Exhibit 7-1 Hepatitis Treatment Guidelines

- Substance Abuse and Mental Health Services Administration’s Division of Pharmacologic Therapies: http://www.dpt.samhsa.gov/comor/hepatitis.aspx
- Practice Guidelines of the American Association for the Study of Liver Diseases: http://www.aasld.org, Practice Guidelines section
- Centers for Disease Control and Prevention: http://www.cdc.gov/hepatitis
- U.S. Department of Veterans Affairs: http://www.hepatitis.va.gov

### Referring Clients to a Hepatitis Treatment Provider

In referring clients for hepatitis care, a major undertaking is finding medical care providers who understand the challenges facing people who have co-occurring hepatitis and SUDs and developing cooperative working relationships with them. Medical care providers might not have the experience or training needed to work with people who have SUDs and hepatitis. When medical care providers lack knowledge about how to treat clients with SUDs, clients are less likely to follow medical advice and more likely to relapse to substance use (Astone-Twerell, Strauss, Hagan, et al., 2006).

To locate health professionals who are experienced in treating hepatitis and sensitive to the needs of people in early recovery, administrators can contact potential partners who indicate an interest in reducing the spread of hepatitis in the community. These partners can include public health departments, nearby teaching hospitals and medical schools, nonprofit hepatitis organizations, and programs that offer HIV treatment. Health departments might be able to provide some hepatitis care for clients and assist with transportation needs. Many clients need assistance in contacting medical service providers (Sylvestre & Zweben, 2007).

### Multidisciplinary Teams

Once a relationship is established with in-house or external medical care providers, a treatment team should be developed. Explicit permission must be obtained from clients to share information among identified clinical staff members. After permission is obtained, collaborative communication among the medical care and substance abuse treatment providers can begin. A case manager, either within the healthcare system or at the substance abuse treatment facility, can promote communication between clients and staff members and treatment providers.

## Prevention and Vaccination

Prevention activities include:

- Providing counseling before and after hepatitis screening.
- Educating clients about the role of injection drug use (IDU), sharing drug paraphernalia, and risky sexual behaviors in virus transmission.
- Providing vaccinations against hepatitis A and B.

Vaccines against hepatitis A virus (HAV) and hepatitis B virus (HBV) exist, but vaccination can be provided most efficiently with the combined hepatitis A/hepatitis B vaccine (sold under the brand name, Twinrix). It is the only U.S. Food and Drug Administration-approved combination hepatitis A and hepatitis B vaccine. The vaccine is administered in three intramuscular injections on a 0-, 1-, and 6-month schedule, or may be given on an accelerated schedule of four doses, given on days 0, 7, and 21–30 with a booster dose at 12 months (FDA, 2010a). Vaccinating clients for HAV and HBV can be done onsite or by referral. State-by-State information on obtaining no-cost vaccinations is available at http://www.hepclinics.com/templates/hepclinic/index.html.

OTPs, which maintain frequent interactions with clients over a long period, are good settings in which to offer hepatitis vaccinations because clients are likely to complete the full vaccination course during treatment. When determining whether to offer onsite hepatitis vaccinations, some questions to consider are:

- Does the facility have sufficient space to store the vaccine and give the injections in private?
- Does the facility have the proper equipment?
- Can the facility follow cold chain (temperature control) procedures to ensure the vaccine is effective?
- Does the facility have staff members licensed to give injections?

Full adherence to HAV and HBV vaccination regimens can be challenging because months separate immunizations. Whether clients are vaccinated at the substance abuse treatment program or at another program or agency, substance abuse treatment program administrators can take the following steps to ensure that clients complete their vaccination regimens:

1. Keep medical records of client’s completed and needed vaccinations.
2. Use reminder tools to alert clients when the next vaccination is scheduled.
3. Allow flexible vaccination schedules (higher doses in a condensed timeframe).
4. Provide transportation to the clinic if the vaccine is administered offsite.
5. Offer incentives if the program’s budget allows (National Alliance of State and Territorial AIDS Directors [NASTAD], 2005).

## Education

Based on research and clinical expertise, the Consensus Panel strongly recommends an increased substance abuse treatment program investment in hepatitis education for all staff members and clients. These investments begin with training staff, learning about community resources available to clients who have chronic hepatitis, and designing education protocols in line with substance abuse treatment programs’ missions and approaches.

### Staff Education

To properly inform clients about hepatitis, staff members must be adequately trained to convey information accurately and completely, and they must be proficient in teaching methods that help clients understand and retain the information presented. Staff preferences and program resources need to be considered when designing hepatitis training. Literature, manuals, and other print materials can be valuable sources for training, but alone they are insufficient. Hands-on opportunities (e.g., classes and workshops that provide an opportunity for role play), are generally more effective than reading print material. Staff members want to learn, for example, how to educate clients about hepatitis C virus (HCV) without alarming clients to the point of impeding their recovery from substance abuse (Munoz-Plaza et al., 2004). Hepatitis training can be incorporated into inservice training schedules. Some training needs are presented in Exhibit 7-2.

Exhibit 7-2 Staff Training for Hepatitis in Substance Abuse Treatment Programs

Service | Topic
Assessment and screening | - Assessing a client’s risk factors of acquiring or transmitting infection; - Obtaining a history of hepatitis disease or vaccination when collecting medical information; - Knowing the procedures for conducting or referring for hepatitis screening; - Counseling before and after screenings; - Assessing potential barriers to screening
Preventing infection (primary prevention) | - Educating clients about the use of drug paraphernalia and risky sexual behaviors to prevent their contracting or transmitting the virus; - Identifying clients in need of hepatitis C treatment or HAV/HBV vaccinations; - Understanding the procedures for referring or providing HAV/HBV vaccinations; - Including hepatitis in client/family educational components; - Collaborating with other agencies (e.g., HIV counseling and testing centers, nonprofit organizations, community outreach agencies, community health clinics, private medical care providers) that treat hepatitis B and C; - Retaining clients who relapse
Limiting disease consequences (secondary prevention) | - Linking clients to hepatitis medical care or providing care onsite; - Promoting medication adherence (e.g., through reminder systems, social support, incentives)
General information and communication | - Research, ethical, and legal issues; - Coordinated care with medical staff members while maintaining client confidentiality; - Quality improvements identified by regular assessment of program components and processes related to hepatitis; - Followups with clients and other medical care providers; - Case management

Several training resources are available, and many are free. Resources for hepatitis training programs developed for substance abuse treatment program staff are presented in Appendix I.

### Client Education

Most substance abuse treatment programs do not offer education about hepatitis to their clients (Strauss, Astone, Hagan, & Des Jarlais, 2004; Strauss et al., 2007). Program budget and audience determine the format and delivery of hepatitis education, which can range from printed matter to educational sessions.

Hepatitis education can be incorporated into the general educational component of the treatment program, with one or more sessions devoted to hepatitis, for example. For clients in OTPs who have chronic hepatitis, more extensive education sessions could be developed. Individual sessions with counselors or other treatment staff members allow clients the opportunity to ask questions, review information, and learn how SUDs affect hepatitis. Chapter 6 provides information for counselors to use to educate their clients. Resources for information on hepatitis are presented in Appendix C.

## Support Services

Some clients will need additional support services, such as services to obtain healthcare coverage from Medicaid or other sources. These clients might also need incentives and intensive case management services to adhere to hepatitis treatment, keep medical appointments, and locate hepatitis support groups. Administrators might need to assign staff members as case managers or work with the medical team to access these services. For example, a medical facility might have transportation services, but the clients might not be aware of them. Information on support groups is in Appendix C. Resources for financial assistance are in Appendix H.

## Outreach

Outreach activities include:

- Joining community leaders, client representatives, and public health officials in providing information about viral hepatitis and substance use.
- Participating in health fairs and taking advantage of other outreach opportunities.
- Building ties to outreach agencies (e.g., HIV counseling and testing centers, community outreach agencies, public health departments, correctional facilities, local hospitals).

In addition to partnering with local agencies and organizations, substance abuse treatment programs that implement hepatitis services can direct outreach and educational activities toward populations at risk for SUDs and viral hepatitis—particularly toward people who inject drugs—to raise awareness of liver disease and risky behaviors, promote screening and early treatment, and encourage vaccination against hepatitis A and B.

Case Study: Support Groups at OASIS, Oakland, California

The Organization to Achieve Solutions in Substance-Abuse (OASIS) developed a peer-based hepatitis C group that provides education, testing, and treatment of HCV infection among people who abuse substances (Sylvestre & Zweben, 2007). It integrates services for hepatitis C, IDU, mental disorders, and psychosocial issues for an inner-city population. The OASIS model demonstrates the ability of a small clinic not associated with major healthcare facilities to implement hepatitis care.

At the model’s core are support groups called Educate-Motivate-Facilitate, in which HCV-knowledgeable peers and a medical provider co-lead groups that address a range of topics. The groups include clients with different knowledge levels and who are at different stages, from hepatitis screening through treatment. As participants become knowledgeable and stable in recovery, they are encouraged to serve as group leaders.

The groups discuss participants’ experience with HCV treatment and side effects, substance use, depression, and other topics. Medical staff members interject correct information or add information, as needed. The interactive format and peer support seem to improve attendance and adherence to medical recommendations.

## Integrating Hepatitis Interventions With Existing HIV Services

Some substance abuse treatment facilities have programs for managing blood-borne infections, such as HIV. The benefits of incorporating hepatitis services within existing HIV services include the following:

- Counselors working with HIV/AIDS are familiar with the challenges of chronic infection and complex therapeutic regimens, as well as with psychosocial issues that accompany a chronic disease.
- Relationships are already established with medical care providers and public health departments.
- Federal or State funding might be available (Strauss et al., 2005; Stringari-Murray, Clayton, & Chang, 2003).

Some substance abuse treatment program staff members have described integrated HCV and HIV services as a “natural fit” (Strauss et al., 2005). With adequate training, counselors can adapt HIV/sexually transmitted disease prevention messages to HCV prevention. Integration need not entail providing all services onsite; it could mean a simple coordinated referral system (NASTAD, 2005).

Administrators who would like to incorporate hepatitis services into existing HIV services should consider the following (Strauss et al., 2005):

- There are different prevention messages for HIV and hepatitis, which are based on different rates of parenteral and sexual transmission.
- Clients often know less about HCV than about HIV.
- Some funding might be dedicated to support services for one virus, while prohibiting funds from being redirected to or shared with other activities.
- Counselors and staff might be reluctant to integrate services.

## Developing Policies and Procedures

Once the workgroup decides which services to implement, policies and procedures need to be established. Examples include:

- Developing an overall policy regarding the program’s approach to providing hepatitis services.
- Implementing and revising policies and procedures to reflect the organization’s goal to provide quality services to clients who need screening or treatment for hepatitis.
- Establishing a system to monitor and evaluate policies and procedures and to revise them, as needed.
- Providing staff development and educational opportunities related to hepatitis.

Writing and implementing new policies and procedures often involve adapting existing ones. Programs might already have a variety of policies and procedures that apply to clients who have hepatitis. For example, most programs probably have policies on what actions to take when a client has an infectious disease, who will work with the client, or where the client could be referred for additional medical treatment. The workgroup can review current policies and procedures to see which ones need to be adapted and revised. Exhibit 7-3 provides an example policy.

Exhibit 7-3 Sample Policy: Screening for Hepatitis

Policy Statement: All counseling staff members will receive training in screening for viral hepatitis and will demonstrate competence in supporting, educating, and referring clients for hepatitis screening.

#### Procedures

1. All counselors will participate in training about hepatitis and its relationship to substance abuse, attitudes toward clients who have hepatitis, and hepatitis screening intervention and referral resources.
2. The clinical supervisor of new employees will provide site-specific information on the procedures for facilitating the screening, treatment, or referral of clients who either are already diagnosed with hepatitis or are at risk for developing hepatitis.
3. Clinical competence checklists completed at hire and annually thereafter will ensure that all clinical staff members (1) have basic knowledge of the benefits of addressing hepatitis with clients who abuse substances, (2) understand the protocols for assessing key risk factors for hepatitis, and (3) are aware of appropriate referral procedures.

## Evaluation

Once the treatment program implements hepatitis services, it can incorporate quality improvements identified by regular evaluation of the new program components and processes. The program can use the existing quality assurance function to develop a tracking system, which could measure the number of clients with hepatitis A, B, and C; hepatitis-related treatment outcomes; and the severity of co-occurring substance use and mental disorders. This information can be used to improve services, to request funding, and to motivate staff.

Case Study: Overcoming Staff Resistance, Minneapolis Healthy Liver Program

The Minneapolis Healthy Liver Program was established in the Minneapolis Veterans Affairs Medical Center Substance Use Disorder Clinic (Hagedorn et al., 2007). A stakeholders group composed of clinical and administrative personnel from the medical center’s substance abuse treatment clinic and hepatitis clinic designed the program. Components included screening for hepatitis A, B, and C, which was added to routine blood work during intake, and intervention, which included a 60-minute group educational session and vaccinations against HAV and HBV, if indicated. As a result:

- Testing rates for HCV increased from 72 percent to 98 percent.
- Testing rates for HAV and HBV increased from less than 20 percent to 98 percent.
- Referral rates of clients newly diagnosed with chronic hepatitis C to a hepatitis clinic increased from 50 percent to 100 percent.

A major challenge was addressing staff resistance to accepting additional responsibility. Lessons learned include:

- Invite staff representatives at all levels—from administration to support— to be represented in a stakeholders’ group.
- Keep general staff informed of stakeholders’ group’s progress via meeting announcements and emails.
- Give staff members an opportunity to comment on the program’s plans and revise the plans based on their concerns.
- Provide staff with ongoing education about potential medical services to improve treatment retention and outcomes.

## Successful Implementation

Munoz-Plaza et al. (2006) analyzed four treatment programs that implemented or expanded hepatitis services. The programs provided educational and social support services (e.g., health education class, hepatitis C education and support sessions, a peer-led hepatitis C seminar). The researchers identified three features that facilitated the implementation of hepatitis services in these programs:

- At least one program administrator promoted efforts to incorporate hepatitis services into the treatment program. At all four programs, supervisory staff encouraged adoption and innovation regarding hepatitis services.
- At least one change agent on staff advocated for the services. One or more people were generally credited for increasing staff awareness about hepatitis, promoting the implementation of hepatitis services, leading the incorporation of hepatitis education and support services, and often taking on associated responsibilities without significant additional compensation. These change agents frequently had a commitment to incorporating hepatitis services, and they often identified themselves as having hepatitis C.
- There was collective buy-in from the substance abuse treatment team. A majority of the staff members at each program eventually supported the incorporation of hepatitis services once they were implemented.

Buy-in from staff members is necessary for success. Administrators can encourage progress by advocating change or supporting staff members’ efforts to implement change. Some staff members are resistant to implementing hepatitis services because they believe these services are outside the scope of substance abuse treatment. Information in Chapters 1–6 of this TIP can mitigate staff members’ resistance for implementing change by helping them understand the numerous links between viral hepatitis and substance use.

## Legal and Ethical Issues

Substance abuse treatment program administrators need current knowledge of the legal and ethical issues about providing hepatitis care and, in particular, about providing medical care to people in their programs. The most significant issues concern confidentiality, informed consent, and staff member rights. Programs that include a peer education component must ensure that peers, like others involved in care, maintain client confidentiality as required by applicable laws and regulations.

### Confidentiality and Privacy Issues

Programs must closely guard information about clients. Although information must be shared with program staff members to the extent necessary to support clients’ needs, its dissemination must be carefully restricted to protect client confidentiality.

The privacy rule under the Health Insurance Portability and Accountability Act (HIPAA) sets limits on how health plans and covered providers might use health information. It allows healthcare providers to share information needed to provide treatment, but it prohibits most other releases of medical information without the client’s authorization. Information about the HIPAA privacy rule as it pertains to substance abuse treatment is available at http://www.hipaa.samhsa.gov.

Substance abuse treatment programs covered under HIPAA must generally comply with longstanding requirements under 42 Code of Federal Regulations (CFR), Part 2, Confidentiality of Alcohol and Drug Abuse Patient Records, which gives substance abuse treatment clients a right to confidentiality. These requirements largely parallel those under the HIPAA privacy rule and prohibit most disclosures of client information unless the client provides consent. Information about 42 CFR is at http://www.gpoaccess.gov/cfr/retrieve.html.

Other Federal and State laws and regulations might govern confidentiality of drug referral and treatment information. For assistance in complying with applicable requirements, treatment programs can request input from State agencies, provider organizations, and legal counsel.

### Informed Consent

Where testing or treatment is involved, informed consent is a legal and ethical prerequisite to administering care. Informed consent ensures that a client understands the therapeutic approach and has the power to make medical decisions. In addition to receiving descriptions of therapeutic options, the client must be informed of the expected risks and benefits. Clients generally have the right to refuse therapeutic interventions and must not be discriminated against based on such decisions.

### Staff Member Rights

All employees whose jobs involve the risk of direct contact with blood or other potentially infectious materials must be offered the hepatitis B vaccination without charge. If they decline, they must sign a form to document the decision.

## Chapter Summary

Administrators can add a variety of viral hepatitis services to their programs, such as:

- Hepatitis screening, evaluation, and diagnosis.
- Hepatitis prevention activities, including education and vaccination.
- Hepatitis treatment or referral to vetted medical care providers for treatment.
- Support services for clients needing hepatitis treatment.
- Outreach to at-risk groups.

Successful programs tend to have:

- At least one administrator to promote efforts to incorporate hepatitis services into the treatment program.
- At least one change agent on staff who advocated for the services.
- Collective buy-in from the treatment team.

Administrators should be familiar with:

- Confidentiality and privacy issues.
- Legal requirements for informed consent.
- Staff member rights pertaining to risks of hepatitis exposure.