# Helping Clients Make Medical Decisions About Hepatitis Treatment

When I was trying to decide whether I should get on the interferon or not, I was hammered until I made a decision. Some medical staff and some clinical staff think because you use drugs that you’re totally stupid, or you’re playing to get time off. There’s got to be a little more compassion and a little more education. They definitely need to let the residents be part of the decision. I mean, it’s their lives.

—Counselor and Former Client in “Program C” (Strauss et al., 2005, p. 1821)

## The Counselor’s Role

Medical care providers that once would have denied hepatitis treatment to people with substance use disorders (SUDs) now routinely screen and evaluate such people and often recommend antiviral treatment. Pharmacotherapy for an opioid addiction, for example, is no longer considered a contraindication to evaluation, care, or treatment of chronic hepatitis (Kresina et al., 2008). Informed counselors can help their clients make decisions about medical care for hepatitis and can support the clients in managing the risks and benefits that come with any decision.

## Factors to Consider About Hepatitis Treatment

People who have chronic viral hepatitis have three options:

1. They can be treated with potent antiviral medications.
2. They can defer antiviral treatment.
3. They can decide not to be treated.

Although antiviral treatment holds the best promise of eliminating chronic hepatitis, the treatment is long, could be difficult, and could be expensive without insurance. (Sources for financial assistance are listed in Appendix H.) Undergoing treatment might not be the best choice for everyone.

The decision to start antiviral treatment should be made by the patient and the medical treatment team, based on the patient’s characteristics, circumstances, and an overall assessment of the treatment risks and benefits. Many times, a patient needs to consult a specialist, such as a hepatologist, to get all the information needed to make a sound decision. Before developing the hepatitis treatment plan, the physician and patient need to consider several factors:

- Timing of hepatitis treatment
- Treatment contraindications
- Presence of more urgent problems
- Likelihood of adhering to hepatitis treatment
- Likelihood of treatment success

### Timing of Hepatitis Treatment

Timing is primarily a factor of how much damage the hepatitis has done to the liver. Patients with mild liver disease (mild scarring), detected by biopsy, might be able to defer hepatitis treatment. Some people, however, might want to do what they can to get rid of their hepatitis C virus (HCV) infection regardless of the state of their liver disease. In this situation, a patient’s feelings about being infected and his or her level of interest in undergoing treatment can be the deciding factors.

Those with intermediate liver disease (intermediate scarring) should seriously consider hepatitis treatment, weighing all relevant factors. For example, people who have HIV co-infection who face the likelihood of an accelerated progression of liver disease have an increased incentive to treat their hepatitis C.

For people who have cirrhosis (severe scarring), timely treatment of hepatitis treatment might be warranted, unless the liver disease has advanced beyond the point that it will respond to antiviral treatment, or the risks of treatment outweigh possible benefits.

Patients with end-stage liver disease (decompensated cirrhosis) might not be appropriate for treatment, unless they are on a transplant waiting list and/or being cared for by experts. Information on hepatitis treatment options, including transplantation, is included in Chapter 5.

### Hepatitis Treatment Contraindications

Some co-occurring medical or behavioral health conditions, certain lifestyle choices, or pregnancy can contraindicate treatment for chronic hepatitis (Ghany, Strader, Thomas, & Seeff, 2009). Contraindications include:

- Major uncontrolled psychiatric disorders (e.g., depression, bipolar, schizophrenia).
- Prior solid organ (i.e., renal, heart, lung) transplantation.
- Pregnancy or unwillingness to use adequate contraception (see Exhibit 4-1).
- A condition that would make hepatitis treatment dangerous (e.g., severe uncontrolled hypertension, untreated heart failure, significant and uncontrolled coronary heart disease, poorly controlled diabetes, chronic pulmonary disease).
- An allergy or hypersensitivity to medications (e.g., interferon, ribavirin).

Exhibit 4-1 Pregnancy and Antiviral Treatment

- Interferon and ribavirin can cause birth defects, so pregnant women (or their sexual partners) should not be administered these medications. Women who are breastfeeding should not undergo antiviral treatment for hepatitis.
- A man receiving antiviral treatment for HCV should not impregnate a woman during his treatment and for 6 months thereafter because of the possible risk of birth defects.
- Women with HCV have to decide whether to complete antiviral treatment before trying to become pregnant or to delay treatment until after delivery.

Use of drugs and alcohol is no longer an absolute contraindication to antiviral treatment (see Exhibit 4-2). Many people who actively inject drugs are not willing to undergo antiviral treatment or might have difficulty adhering to treatment. However, some people who use drugs, including people who inject drugs, are willing and able to undergo and adhere to antiviral treatment (Ghany et al., 2009).

Exhibit 4-2 Statements and Recommendations on Hepatitis Treatment

Agency | Treatment Guideline
National Institutes of Health Consensus Statement on the Management of Hepatitis C | Decisions about treatment of hepatitis C in people who inject drugs should be made on a case-by-case basis; drug use itself is not an absolute contraindication to antiviral treatment for hepatitis C (National Institutes of Health [NIH], 2002).
New York State Department of Health Guidelines for the Medical Management of Hepatitis C | “Patients actively using injection drugs should be offered drug counseling and psychiatric support services.… [T]reatment of the actively injecting drug using person should be based upon the willingness of the client to undergo therapy, ability to regularly attend appointments for close monitoring, and agreement to use of contraception to prevent pregnancy” (New York State Department of Health, 2005a, p. 11).
American Association for the Study of Liver Diseases Guidelines on Diagnosis, Management, and Treatment of Hepatitis C | Therapy should be individualized for people who currently use alcohol and who are willing to participate in a substance abuse or alcohol treatment support program (Ghany et al., 2009).

### Presence of More Urgent Problems

Some health issues might take precedence over beginning treatment for hepatitis, particularly if the extent of liver damage is mild or intermediate:

- Treatments for HIV infection or other life-threatening conditions might need to begin first.
- Stabilization of a mental or substance use disorder might be necessary.
- The priority of some clients might be to meet basic needs (e.g., finding housing; getting regular, nutritious meals).
- Clients in crisis might need to stabilize before antiviral treatment can begin, depending on the number and severity of stressors in their lives.

### Likelihood of Adhering to Hepatitis Treatment

It is difficult to predict which individuals can or will adhere to hepatitis treatment. Until recently, the standard practice was to recommend against treating chronic hepatitis in people whose circumstances or conditions might interfere with their ability to adhere to treatment (e.g., continued substance abuse, mental illness). But this is no longer the case. The following points summarize the current thinking on treating people who have conditions previously considered contraindications to antiviral treatment:

- Hepatitis C treatment is associated with exacerbation of existing psychiatric symptoms, new symptoms, and thoughts of suicide. Depression is a common side effect of antiviral treatment and a main reason people stop treatment. However, with psychiatric treatment and monitoring, people who have psychiatric disorders have rates of adherence and successful outcome comparable with rates of those who do not have psychiatric disorders (Martin-Santos et al., 2008).
- People in opioid treatment programs sometimes have structured support, which helps them adhere to antiviral treatment and have successful outcomes.
- People who relapse to alcohol or injection drug use can sometimes successfully complete antiviral treatment at rates that do not significantly differ from those of people who do not abuse substances (Anand et al., 2006; Backmund, Meyer, & Edlin, 2004; Dalgard, 2005; Robaeys, Van Vlierberghe, Mathei, Van Ranst, & Buntinx, 2006; Van Thiel, Anantharaju, & Creech, 2003).

### Likelihood of Hepatitis Treatment Success

Hepatitis C treatment success is defined as achieving a sustained virologic response (SVR) (see Exhibit 4-3)—when the virus cannot be detected for up to 24 weeks (and usually many years) after therapy. If the virus cannot be eradicated, treatment is generally considered unsuccessful, even though the progression of liver disease might have slowed during treatment. For individuals with mild liver disease, a higher predicted likelihood of achieving an SVR might make them more interested in antiviral treatment than individuals whose expected likelihood of responding is lower. Historically, success rates for those who received hepatitis treatment were between 40 percent and 50 percent (Heathcote & Main, 2005), but new therapies promise higher success rates and shorter treatment times.

Exhibit 4-3 Hepatitis C Treatment Response Classifications

Treatment Outcome | Description
Sustained virologic response (SVR) | The virus is absent from the blood at the end of treatment and 6 months later. SVR is considered a successful treatment response.
Non-response | Antiviral treatment does not work, meaning the virus can be detected in viral load tests. If the level of virus does not decrease by one hundredfold after 12 weeks of treatment, or if it does not go away completely after 24 weeks, treatment is unsuccessful and can be stopped.
Virologic relapse | The virus disappears from the blood during antiviral treatment but returns when treatment is stopped.

Several factors affect the likelihood of treatment success:

- Genotypes. Clients who are infected with HCV genotype 2 or 3 have approximately an 80 percent chance of success, as opposed to as much as a 67 percent to 68 percent chance for those who are infected with genotype 1 (see Chapter 3).
- Viral load. Treatment response rates tend to be low for those with genotype 1 HCV infection and high pretreatment viral load (see Chapter 3).
- Ethnicity. For reasons that are not understood but might be related to genetic factors (Balagopal, Thomas, & Thio, 2010), hepatitis treatment response rates are low among Blacks and Hispanics, compared with rates among Whites and Asians (Conjeevaram et al., 2006; Rodriguez-Torres et al., 2009).
- HIV co-infection. Response rates are lower in individuals with HIV co-infection.
- Liver damage. People who have extensive liver damage are less likely to respond to hepatitis treatment than those with moderate or low liver damage, although treatment is more urgent for people who have severe liver damage.

## Counseling Clients Diagnosed With Chronic Hepatitis

Exhibit 4-4 lists potential counseling approaches to various HCV evaluation results. Individual circumstances vary, and treatment decisions will ultimately reflect advice from a medical professional working in concert with the client. For clients who are considering antiviral treatment, counselors can:

- Encourage clients to ask their medical care provider for the information needed to make informed decisions about treatment.
- Encourage thorough, informed consideration of treatment.
- Encourage clients to take action toward improved health or life circumstances.
- Assess mental health and SUD recovery statuses.
- Emphasize the importance of alcohol abstinence.
- Help clients strengthen their support systems.

Exhibit 4-4 Counseling Approaches Based on HCV Status

Evaluation Result | Hepatitis Treatment Approach | Counseling Approach
- No evidence of liver damage; - No HCV found in blood (negative antibody test); might need to retest in 6 months | - No HCV antiviral treatment needed | - Educate client about liver health; - Create risk-reduction plan; - Encourage vaccination against hepatitis A virus (HAV) and hepatitis B virus (HBV)
- Evidence of mild liver damage; - HCV ribonucleic acid (RNA) found in blood; - Stable mental/physical health and life circumstances | - Consider antiviral treatment; - Monitor liver health | - Educate client about liver health; - Create risk-reduction plan; - Encourage vaccination against HAV and HBV; - Encourage thorough, informed consideration of hepatitis treatment
- Evidence of mild liver damage; - RNA found in blood; - Unstable mental/physical health or life circumstances | - Defer antiviral treatment; - Stabilize health and life circumstances; - Monitor liver health | - Educate client about liver health; - Create risk-reduction plan; - Encourage vaccination against HAV and HBV; - Encourage action toward improved health and/or life circumstances
- Evidence of severe liver damage; - HCV RNA found in blood; - Stable or unstable mental/physical health and life circumstances | - Consider antiviral treatment; - Monitor and stabilize health or life circumstances | - Encourage treatment adherence; - Educate client about liver health; - Create risk-reduction plan; - Encourage vaccination against HAV and HBV; - Encourage action toward improved health and/or life circumstances
- HCV RNA found in blood; - Genotype 2 or 3; - Stable or unstable mental/physical health or life circumstances | - Urge antiviral treatment; - Stabilize health and life circumstances as necessary | - Encourage treatment adherence; - Educate client about liver health; - Create risk-reduction plan; - Encourage vaccination against HAV and HBV; - Encourage action toward improved health and/or life circumstances
- End-stage liver disease, regardless of other factors | - Consider liver transplantation | - Encourage vaccination against HAV and HBV; - Encourage action toward meeting requirements for transplantation

Counselors can explain the following information to clients:

- If hepatitis treatment does not completely clear the virus, some benefit might still occur (e.g., lower viral levels, less inflammation or fibrosis) (NIH, 2002). Also, many people who have hepatitis C do not develop cirrhosis, end-stage liver disease, or liver cancer.
- The length of antiviral treatment varies.
- Clients will need to get frequent lab tests to ensure medication tolerance and effectiveness.
- If side effects are too severe or if the medication is not working, the medical care provider might reduce the dose or stop treatment altogether. This does not mean the client failed; it means that the treatment failed. It should be noted, however, that the client might still receive some benefit from treatment even though treatment was not completed (NIH, 2002). Nonresponse to treatment does not mean that liver damage is more severe.

## Supporting the Decision to Treat Hepatitis

For many clients who have chronic hepatitis, the decision to initiate hepatitis treatment is difficult. Some clients might feel an urgent need to undergo aggressive antiviral treatment. Others might feel that treatment, even if strongly recommended by their medical care provider, is not right for them, or they want to wait until they are further along in their recovery from substance use. Questions to help clients weigh their hepatitis treatment options include the following:

- “What are the possible gains and losses of your decision to get or not to get antiviral treatment?”
- “Which of these are most important to you?”
- “If you’re not ready to begin hepatitis treatment now, what would have to happen to get you ready or make you decide to begin treatment?”
- “What would you be interested in doing now?”

Only the client, in conjunction with his or her medical care provider, can decide whether antiviral treatment is the right choice. After discussing the benefits and risks of treatment in the context of the client’s life, the counselor should respect and support the client’s decision. Counselors can help clients who undertake antiviral treatment adhere to the regimen, as well as help those who defer treatment understand how to promote and maintain liver health.

Clinical Scenario

Selena is a 36-year-old Hispanic woman who has been in outpatient treatment for opioid dependence for 2 months after completing detoxification and a residential treatment program. Her HCV treatment has caused side effects that feel like opioid withdrawal, which has triggered cravings for oxycodone. She stated in her last meeting with her counselor that she is going to stop taking her hepatitis medications to avoid relapsing. What should the substance abuse treatment team do in response to this situation?

#### Primary Concerns

- Selena wants to stop taking her hepatitis medications.
- Selena might not be ready to tolerate the side effects of antiviral treatment.
- Selena needs stronger coping skills for managing her cravings.

#### Intervention Options

- In consultation with her medical care provider, help her weigh the risks and benefits of stopping antiviral treatment and how it can be done safely.
- Discuss ways to help Selena manage her current cravings (e.g., ongoing counseling, support groups, referral to an intensive outpatient program or a residential treatment program, increased or random urine drug testing and other monitoring, waiting until she is further along in her recovery from using opioids to resume hepatitis medications).
- Help Selena understand that she can restart antiviral treatment at a later date.
- Discuss the possibility of starting opioid maintenance treatment if she is not already on medication-assisted treatment.

## Special Populations: Barriers to Hepatitis Treatment

Many people might have to overcome barriers to screening and treatment of chronic hepatitis, including people who are homeless or incarcerated; people who have mental illness; members of ethnic, racial, or gender minorities; people whose first language is not English; and others. Although conditions differ among populations and individuals, the needs of marginalized people are often similar. Counselors can assist these clients by:

- Helping them obtain basic information about all types of hepatitis in a format or language they can understand.
- Encouraging them to get vaccinated against hepatitis A and B.
- Advocating screening and treatment when the medical care provider’s reluctance to treat is based solely on the SUD diagnosis.
- Helping clients find medical care providers who are familiar with and understanding of their culture or subculture.
- Making referrals to specialized case management services for shelter services, housing, food, and other basic needs.
- Understanding marginalized clients’ distrust of medical care systems and public health surveillance requirements.
- Helping clients understand and navigate complex medical care requirements.
- Monitoring for the co-occurrence of mental and substance use disorders, especially for the worsening of psychiatric symptoms when HCV treatment begins, and managing care or referring for specialized care, as indicated.

Appendix C includes resources available for people facing particular barriers to treatment.

## Chapter Summary

In determining eligibility for treatment of viral hepatitis, medical care providers consider:

- Timing of hepatitis treatment.
- Treatment contraindications.
- The presence of more urgent problems.
- The likelihood of patients’ adhering to hepatitis treatment.
- The likelihood of treatment success.

Medical care providers, clients, and counselors should work together to consider the advisability of antiviral treatment.

There is growing consensus that people who have injected or still inject drugs can be successfully treated for hepatitis.

Steps to help clients decide whether to begin antiviral treatment include:

- Helping clients understand the meaning of evaluation results for hepatitis treatment.
- Assessing clients’ SUD recovery, mental health issues, support systems, and life circumstances.
- Educating clients about their choices.
- Helping clients reframe goals of recovery to include a meaningful, healthy life.

Once a client makes a decision about hepatitis treatment, the counselor should support that decision and offer to reconsider in the future if circumstances change.

Clients from special populations might require additional education or advocacy. Their unique needs must be considered in antiviral treatment planning.