# Acknowledgments

Numerous people contributed to the development of this Treatment Improvement Protocol (TIP), including the TIP Consensus Panel (p. xiii), stakeholders (Appendix J), and field reviewers (Appendix K).

This publication was written and produced under contract numbers 270-04-7049 and 270-09-0307, by the Knowledge Application Program (KAP), a Joint Venture of JBS International, Inc., and The CDM Group, Inc., for the Center for Substance Abuse Treatment (CSAT), Substance Abuse and Mental Health Services Administration (SAMHSA), U.S. Department of Health and Human Services (HHS).

Lynne MacArthur, M.A., A.M.L.S., served as the JBS KAP Executive Project Co-Director, and Barbara Fink, RN, M.P.H., served as the JBS KAP Managing Project Co-Director. Other JBS KAP personnel included Candace Baker, M.S.W., MAC, Deputy Director for Product Development; Deborah Steinbach, M.A., Senior Writer; Patricia Kassebaum, M.A., Senior Writer; Kris Rusch, M.A., Senior Writer; Martha J. Horn, Ph.D., Senior Writer; Frances Nebesky, M.A., Quality Assurance Editor; Wendy Caron, Quality Assurance Manager; Erin P. Doherty, Copy Editor; Terrie Young, Graphic Designer; and Erin Sandor, Graphic Designer.