# Field Reviewers

Corinna Dan, RN, M.P.H.

Hepatitis Foundation International

Silver Spring, Maryland

Brenda Davis

Clinic Manager

Beth Israel Medical Center

Methadone Maintenance Treatment Program

New York, New York

Leonard Gill

President, HCV Peer Educator/Patient Advisory Committee

Albert Einstein College of Medicine

Division of Substance Abuse

Bronx, New York

Carol L. Kuprevich, Ed.D.

Director of Community Planning, Program Development, and Training

Delaware Division of Alcohol, Drug Abuse and Mental Health

New Castle, Delaware

Shirley Mikell

NAADAC—The Association for Addiction Professionals

Alexandria, Virginia

Rosa Rodriguez

Substance Abuse Counselor

Albert Einstein College of Medicine

Peekskill, New York

Leonard B. Seeff, M.D.

Senior Scientist for Hepatitis Research

National Institute of Diabetes and Digestive and Kidney Diseases, Division of Digestive Diseases and Nutrition

National Institutes of Health

Bethesda, Maryland

Carol Sholiton

President and Founder

Methadone Support Org

Scottsdale, Arizona

Dee-Dee Stout, M.A., CADC II,

MINT

Director

Responsible Recovery

Emeryville, California

Lynn E. Sullivan, M.D.

Assistant Professor of Medicine

Yale University

New Haven, Connecticut

Lynn E. Taylor, M.D.

Assistant Professor of Medicine

The Warren Alpert Medical School of Brown University

Providence, Rhode Island

Thelma King Thiel, RN

Chair and Chief Executive Officer

Hepatitis Foundation International

Silver Spring, Maryland

Jeanne Wells

Social Worker

Rocky Mountain Health Services

Woodland Park, Colorado

Kimberly Wright

Medical Services Coordinator

Missouri RAIN

Columbia, Missouri and

National Institute of Diabetes and Digestive and Kidney Diseases

National Institutes of Health

Bethesda, Maryland