# Stakeholders Meeting Participants

Cheryl Anderson

Bureau of Primary Health Care Quality Improvement

Health Resources and Services Administration

Rockville, Maryland

Joanna Buffington, M.D., M.P.H.

Medical Officer

Prevention Branch, Division of Viral Hepatitis

Centers for Disease Control and Prevention

Atlanta, Georgia

H. Westley Clark, M.D., J.D., M.P.H., CAS, FASAM

Director

Center for Substance Abuse Treatment

Substance Abuse and Mental Health Services Administration

Rockville, Maryland

Edwin M. Craft, Dr.P.H.

Lead Government Project Officer, Methamphetamine

Center for Substance Abuse Treatment

Substance Abuse and Mental Health Services Administration

Rockville, Maryland

Christina Currier

Government Project Officer

Center for Substance Abuse Treatment

Substance Abuse and Mental Health Services Administration

Rockville, Maryland

David A. Fiellin, M.D., Chair

Professor of Medicine and of Public Health and Associate Professor of Investigative Medicine

Yale University School of Medicine

New Haven, Connecticut

Robert Hendricks

Special Assistant to the Director

Center for Substance Abuse Treatment

Substance Abuse and Mental Health Services Administration

Rockville, Maryland

Warren Hewett, Jr.

AIDS Coordinator

Center for Substance Abuse Treatment

Substance Abuse and Mental Health Services Administration

Rockville, Maryland

Kirk E. James, M.D.

Medical Officer

Systems Improvement Branch

Center for Substance Abuse Treatment

Substance Abuse and Mental Health Services Administration

Rockville, Maryland

Leslye D. Johnson, Ph.D.

Chief, Enteric and Hepatic Diseases Branch

Division of Microbiology and Infectious Diseases

National Institute of Allergy and Infectious Diseases

National Institutes of Health

Bethesda, Maryland

Stella P. Jones, M.S.W., LICSW, BCD

Senior Program Management Officer

Center for Substance Abuse Treatment

Substance Abuse and Mental Health Services Administration

Rockville, Maryland

Jag H. Khalsa, Ph.D.

Chief, Medical Consequences Branch, DPMC

National Institute on Drug Abuse

National Institutes of Health

Bethesda, Maryland

Andrea Kopstein, Ph.D., M.P.H.

Practice Improvement Branch Chief

Division of Services Improvement

Center for Substance Abuse Treatment

Substance Abuse and Mental Health Services Administration

Rockville, Maryland

Thomas F. Kresina, Ph.D.

Senior Public Health Advisor

Division of Pharmacologic Therapies

Center for Substance Abuse Treatment

Substance Abuse and Mental Health Services Administration

Rockville, Maryland

Robert Lubran, M.S., M.P.A.

Director

Division of Pharmacologic Therapies

Center for Substance Abuse Treatment

Substance Abuse and Mental Health Services Administration

Rockville, Maryland

Eileen M. McGrath, J.D.

Executive Vice President

American Society of Addiction Medicine

Chevy Chase, Maryland

Shirley Mikell

NAADAC—The Association for Addiction Professionals

Alexandria, Virginia

Daniel Raymond

Policy Director

Harm Reduction Coalition

New York, New York

Leonard B. Seeff, M.D.

Senior Scientist for Hepatitis Research

National Institute of Diabetes and Digestive and Kidney Diseases

National Institutes of Health

Bethesda, Maryland

Dennis Simon

Secretary/Treasurer

Hepatitis C Association

Scotch Plains, New Jersey

Jack Stein, M.S.W., Ph.D.

Director

Division of Services Improvement

Center for Substance Abuse Treatment

Substance Abuse and Mental Health Services Administration

Rockville, Maryland

Chris Taylor

Viral Hepatitis Program Manager

National Alliance of State and Territorial AIDS Directors

Washington, D.C.

Thelma King Thiel, RN

Chair and Chief Executive Officer

Hepatitis Foundation International

Silver Spring, Maryland

David C. Thompson

HIV/AIDS Team Leader

Center for Substance Abuse Treatment

Substance Abuse and Mental Health Services Administration

Rockville, Maryland

Mary R. Vienna

Health Resources and Services Administration

Rockville, Maryland