# Hepatitis C Training Programs for Substance Abuse Treatment Program Staff

Focus on Hepatitis C was developed by the Hepatitis C Association, sponsored by the Substance Abuse and Mental Health Services Administration. The 3-hour training includes a PowerPoint presentation, a question-and-answer session, and a discussion of local resources. Content includes functions of the liver, risk factors, modes of transmission, diagnostic process and treatment of HCV, natural history and progression of HCV and HCV/HIV co-infection, healthful lifestyle choices that preserve liver health, counseling guidelines, and issues and challenges in providing care for clients with hepatitis C in treatment centers. Training provides information on locating community resources; Web sites, toll-free support lines, and venues for medical care; and information on obtaining treatment assistance for people who are not insured or are underinsured. Continuing education credits can be earned (http://www.hepcfocus.com).

- The Centers for Disease Control and Prevention (CDC) maintains numerous trainings and resources (http://www.cdc.gov/ncidod/diseases/hepatitis/resource/training/counseling.htm).
- HCV Advocate offers training resources and information from the client’s perspective (http://www.hcvadvocate.org/hepatitis/training_resources.asp).
- CDC’s Division of Viral Hepatitis provides funding to HCV coordinators across the country to offer viral hepatitis counseling, testing, vaccinations, and other services (http://www.cdc.gov/hepatitis/index.htm).
- Pharmaceutical manufacturers of hepatitis medications are often willing to conduct free onsite training sessions for counseling staff. Contact manufacturers directly.