# Sources for Financial Assistance

- A source for identifying government sources of healthcare and support benefit programs by State. (http://www.benefits.gov/)
- Low-income clients might be eligible for Medicaid, but benefits vary significantly across States. (http://cms.hhs.gov)
- Federally funded health centers provide medical services to people who are uninsured and underinsured. (1-800-ASK-HRSA [1-800-275-4772]).
- The Veterans Healthcare System offers hepatitis C virus screening, treatment, and support services to eligible U.S. veterans.
  (http://www.hepatitis.va.gov)
- The Ryan White CARE Act provides medications to eligible low-income U.S. residents who have HIV, including those co-infected with hepatitis. (http://hab.hrsa.gov)
- Needymeds.org is a consumer site providing sources on pharmaceutical, State, Medicare, and Medicaid financial support for the treatment of serious diseases, including hepatitis.
  (http://www.needymeds.org/)
- Partnership for Prescription Assistance is a pharmaceutical-company-sponsored resource that offers low- or no-cost medication to people who lack prescription drug coverage.
  (http://www.pparx.org)
- National Foundation for Transplants helps individuals find financial support for transplantation operations.
  (http://www.transplants.org)
- National Transplant Assistance Fund raises funds for uninsured medical expenses related to transplantation.
  (http://www.transplantfund.org)
- Hepatitis clinical trials are available to a limited number of people. (http://clinicaltrials.gov/ct2/results?term=hepatitis)