# Motivational Interviewing and Counseling Resources

- Case Management Adherence Guidelines, Version 2.0 (Case Management Society of America, 2006), http://www.cmsa.org/portals/0/pdf/CMAG2.pdf
- Enhancing Motivation for Change in Substance Abuse Treatment (Center for Substance Abuse Treatment [CSAT], 1999), http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=hssamhsatip&part=A61302
- Enhancing Motivation for Change Inservice Training (CSAT, 2006), http://www.kap.samhsa.gov/products/manuals/tip35c/index.htm
- Group Treatment for Substance Abuse: A Stages-of-Change Therapy Manual. M. Velasquez, G. Maurer, C. Crouch, & C. DiClemente. New York: Guilford Press, 2001
- Motivational Groups for Community Substance Abuse Programs. K. Ingersoll, C. Wagner, & S. Gharib. Kansas City: Addiction Technology Transfer Center Network, 2000
- Motivational Interviewing: Preparing People for Change, 2nd ed. W. Miller & S. Rollnick. New York: Guilford Press, 2002
- The Motivational Interviewing Web Page, http://www.motivationalinterview.org