# Medicinal Plants/Alternative Treatments Potentially Harmful to People Who Have Hepatitis

Clients who have hepatitis should check with their medical care providers before taking nutritional supplements or alternative treatments. The substances listed below might harm the liver.

Artemisia (mugwort, sagebrush, wormwood)

Aspalathus linearis (bush tea)

Atractylis gummifera (pine thistle)

Callilepis laureola

Crotalaria

Ephedra sinica (ma huang)

Gnaphalium (Gordolobo herbal tea)

Hedeoma (pennyroyal, squaw mint oil)

Heliotropium

Iron supplements

Kombucha mushroom tea

Larrea tridentata (chaparral leaf, creosote bush, greasewood)

Margosa oil

Mate (Paraguay) tea

Myristica (nutmeg)

Piper methysticum (kava)

Sassafras

Scutellaria lateriflora (skullcap)

Senecio aureus

Senecio jacobaea (tansy ragwort, variation of ragwort)

Senna

Symphytum officinale (comfrey)

Valeriana officinalis (valerian root)

Viscum album (mistletoe)

Vitamin A supplements

Yerba tea

Source: Alternative and Complementary Therapies, U.S. Department of Veterans Affairs, http://www.hepatitis.va.gov/patient/alternative-therapies/index.asp