# Managing Side Effects of Hepatitis C Antiviral Treatment

Side Effect | Potential Management Strategy
Bad taste in mouth | - Try sugar-free lemon drops or lemon wedges.; - Eat a small amount of yogurt ½ hour before meals.; - Eat dark chocolate or drink lemonade or cranberry juice.; - Eat food cold or at room temperature.; - Brush teeth frequently.; - Use plastic utensils if experiencing metallic taste.
Cough | - Increase fluid intake (noncaffeinated).; - Use a humidifier.; - Try sugar-free hard candy or cough drops.
Diarrhea | - Eat more fiber foods like bananas, white rice, applesauce, and white toast (the BRAT diet).; - Avoid spicy or acidic foods (like citrus) and dairy products for several days after diarrhea resolves.; - Drink plenty of fluids (six to eight 8-oz glasses/day).
Dry mouth or mouth ulcers | - Brush teeth frequently, especially after eating.; - Avoid mouthwash containing alcohol.; - Drink plenty of water or use ice chips or sugar-free lemon drops.; - Ask medical care provider about medications for mouth sores/ulcers.
Dry skin/rashes | - Avoid long, hot showers or baths.; - Use moisturizing soap and lotions, sunscreen, and mild unscented laundry detergents.; - Avoid fabric softeners.; - Rub or press on the itchy areas rather than scratch them.; - Use petroleum jelly on affected areas and ask medical care provider about other solutions.
Fatigue | - Try low-impact exercise such as walking or low- impact aerobics, if approved by medical care provider.; - Drink plenty of fluids and get plenty of rest.; - Lessen work schedule if possible.; - Eat well-balanced meals every day.
Fever/Chills | - Notify medical care provider if the temperature is above 101°F for more than 24 hours.; - Inject interferon at bedtime.; - Take acetaminophen 30–60 minutes before weekly interferon injection and repeat 4–6 hours later, if approved by medical care provider.; - Use ibuprofen or naproxen, if approved by medical care provider.; - Try a cool sponge bath, ice pack, or cold pack.; - Use extra blankets and clothes.
Hair thinning or hair loss | - Avoid harsh hair products such as dyes, perms, gels, sprays, and mousses.; - Use mild shampoo such as baby shampoo.; - Avoid braiding hair.; - Use a wide-tooth comb or soft brush.
Headaches | - Drink plenty of fluids and get plenty of rest.; - Try taking acetaminophen or ibuprofen, if approved by medical care provider.; - Keep lights dim, wear sunglasses, or stay in darkened rooms.
Injection site reactions | - Warm the vial by gently rolling it in between two hands for a minute before injecting.; - Rotate injection sites—thigh, upper arm, and abdomen.; - Do not inject into an area that is irritated, bruised, or red.; - Do not rub injection site.; - Apply a cold pack.; - Apply hydrocortisone cream or other medications, if approved by medical care provider.
Insomnia | - Go to bed and get up at the same times every day.; - Do not read or watch TV in bed.; - Limit daytime naps.; - Take ribavirin in the late afternoon instead of before bedtime, if it causes the jitters.; - Limit fluid intake for 2 hours before bedtime to avoid getting up to go to the bathroom.; - Avoid caffeinated products, especially in the afternoon and at night.; - Avoid heavy meals close to bedtime.; - Take warm baths, read or listen to music, get a massage.; - Drink a glass of warm milk (contains tryptophan, a natural sleep agent).; - Take diphenhydramine (Benadryl) or other medications recommended by medical care provider.
Muscle and body aches | - Try low-impact exercise such as walking or low-impact aerobics, if approved by medical care provider.; - Drink plenty of fluids, at least six to eight noncaffeinated 8-oz glasses/day.; - Apply warm moist heat or massage affected areas.
Nausea and vomiting | - Take ribavirin with food.; - Eat small meals.; - Avoid foods or smells that trigger nausea; eat cold foods and avoid cooking smells.; - Eat healthful foods; avoid greasy, spicy, acidic, or sweet foods.; - Try ginger tea, ginger ale, or gingersnaps.; - Eat crackers or dry white toast for morning nausea.
Poor appetite | - Eat small, more frequent (4–6) meals throughout the day.; - Try protein drinks and snacks (cheese, peanut butter, eggs).; - Eat whatever appeals to you even if not hungry; eat a variety of foods.; - Walk before a meal.

Source: National Hepatitis C Program, U.S. Department of Veterans Affairs, http://www.hepatitis.va.gov/pdf/treatment-side-effects.pdf