# Hepatitis Resources

Organization | Contact Information | Topics Covered
American Association for the Study of Liver Diseases | http://www.aasld.org/Pages/Default.aspx 1-703-299-9766 | - Hepatitis A; - Hepatitis B; - Hepatitis C; - Biopsy; - Transplantation (members only)
American Liver Foundation | http://www.liverfoundation.org 1-800-405-4837 | - Hepatitis A; - Hepatitis B; - Hepatitis C; - Support groups; - Information for special populations; - Patient education materials; - Resources in English and other languages
Centers for Disease Control and Prevention | http://www.cdc.gov/ncidod/diseases/hepatitis 1-800-232-4636 | - Hepatitis A; - Hepatitis B; - Hepatitis C; - Information for special populations; - Patient education materials; - Resources in English and other languages
Department of Veterans Affairs | http://www.hepatitis.va.gov | - Hepatitis A; - Hepatitis B; - Hepatitis C; - Biopsy (for medical care providers); - Transplantation; - Information for special populations; - Patient education materials
HCV Advocate | http://www.hcvadvocate.org | - Hepatitis B; - Hepatitis C; - Biopsy; - Support groups; - Information for special populations; - Patient education materials; - Resources in English and other languages
Hepatitis B Foundation | http://www.hepb.org 1-215-489-4900 | - Hepatitis B; - Support groups; - Information for special populations; - Patient education materials; - Resources in English and other languages
Hepatitis C Association | http://www.hepcassoc.org 1-866-437-4377 | - Hepatitis C; - Support groups; - Information for special populations; - Patient education materials
Hepatitis C University | http://www.hcvu.org/et_patient.php 1-877-428-8123 | - Resources for medical care providers
Hepatitis Education Project | http://www.hepeducation.org 1-206-732-0311 | - Hepatitis A; - Hepatitis B; - Hepatitis C; - Support groups; - Transplantation; - Information for special populations; - Patient education materials
Hepatitis Foundation International | http://www.hepfi.org 1-800-891-0707 | - Hepatitis A; - Hepatitis B; - Hepatitis C; - Support groups; - Information for special populations; - Patient education materials; - Resources in English and other languages
HepClinics | http://www.hepclinics.com/templates/hepclinic/index.html | - Hepatitis A; - Hepatitis B; - Information for special populations; - Patient education materials
Immunization Action Coalition | http://www.immunize.org 1-651-647-9009 | - Hepatitis A; - Hepatitis B; - Information for special populations; - Patient education materials; - Resources in English and other languages
Indian Health Service | http://www.ihs.gov | - Hepatitis A; - Hepatitis B; - Hepatitis C; - Information for special populations; - Patient education materials
Massachusetts General Hospital | http://www.mgh.harvard.edu/default.aspx 1-617-726-2000 | - Hepatitis A; - Hepatitis B; - Hepatitis C; - Biopsy
Medline Plus | http://www.nlm.nih.gov/medlineplus/tutorials/hepatitisc/htm/index.htm | - Hepatitis C
Methadone Anonymous Support | http://www.MethadoneSupport.org | - Hepatitis C; - Support groups (for methadone); - Resources in English and other languages
National AIDS Treatment Advocacy Project | http://www.natap.org 1-888-266-2827 | - Hepatitis B; - Hepatitis C; - Transplantation; - Patient education materials
National Digestive Diseases Information Clearinghouse | http://digestive.niddk.nih.gov 1-800-891-5389 | - Hepatitis A; - Hepatitis B; - Hepatitis C; - Biopsy; - Transplantation; - Resources in English and other languages
National Foundation for Transplants | http://www.transplants.org 1-800-489-3863 | - Transplantation; - Resources in English and other languages
National Hepatitis C Advocacy Council | http://www.hepcnetwork.org | - Hepatitis C; - Resources in English and other languages
National Transplant Assistance Fund | http://www.ntafund.org 1-800-642-8399 | - Transplantation; - Resources in English and other languages
New York State Office of Alcoholism and Substance Abuse Services | http://www.oasas.state.ny.us/admed/documents/HEPATITIS.pdf | - Hepatitis A; - Hepatitis B; - Hepatitis C
StopHep.Com | http://www.stophep.com/StopHep | - Hepatitis A; - Hepatitis B; - Hepatitis C; - Patient education materials; - Special populations
Transplant Recipients International Organization | http://www.trioweb.org 1-800-874-6386 | - Support services; - Transplantation