# Glossary

acetaminophen: The generic name for a common nonprescription medication used to treat mild pain or fever.
acute hepatitis: An inflammatory process in the liver that resolves in 6 months.
adefovir dipivoxil: A U.S. Food and Drug Administration-approved antiviral medication for treating chronic hepatitis B, taken orally.
alanine aminotransferase (ALT): An enzyme found in the liver; an increased level of ALT in the blood indicates liver inflammation.
albumin: A protein made in the liver that helps move small molecules through the bloodstream. It plays an important role in keeping the fluid from the blood from leaking into the tissues. If albumin drops to very low levels, fluid might leak into tissues from the blood vessels, resulting in edema (swelling).
alkaline phosphatase (ALP): An enzyme found in the liver and other parts of the body; elevated levels might indicate liver injury.
antibody: A type of protein produced by the body’s immune system. Antibodies protect the body from disease by binding to antigens (see below) and destroying them.
antigens: Foreign substances (e.g., bacteria, viruses) in the body that are capable of causing disease. The presence of antigens in the body triggers an immune response, usually the production of antibodies (see above).
antiviral (literally against-virus): Any medicine capable of destroying or weakening a virus or suppressing its ability to replicate.
aspartate aminotransferase (AST): An enzyme found in the liver; an increased level of AST in the blood indicates liver inflammation.
asymptomatic: Presenting no symptoms of disease.
boceprevir: A U.S. Food and Drug Administration-approved medication for treating chronic hepatitis C, taken orally.
chronic hepatitis: An inflammatory process in the liver that lasts longer than 6 months.
cirrhosis: Irreversible scarring of the liver caused by ongoing damage, which might affect liver function. Cirrhosis in some cases can lead to liver failure, liver cancer, and death.
co-infection: The condition of an organism or cells being infected simultaneously by two different pathological microorganisms, such as infection with both hepatitis C virus and HIV.
contagious: Capable of being transmitted from one person to another by contact or close proximity.
coronary heart disease: A narrowing of the small blood vessels that supply blood and oxygen to the heart. Also called coronary artery disease.
decompensated cirrhosis: A progression of cirrhosis that can be life threatening. Symptoms include internal bleeding, large amount of fluid in the abdomen, encephalopathy (confusion), and jaundice.
end-stage liver disease: Severe damage to the liver. End-stage complications include liver failure and liver cancer. These conditions occur primarily in people who develop permanent scarring of the liver (cirrhosis).
entecavir: An oral prescription medicine used for chronic infection with hepatitis B virus in adults.
enzyme: A protein (or, rarely, ribonucleic acid) that catalyzes a chemical reaction; it is produced by living cells and catalyzes specific biochemical reactions at body temperatures.
exposure: Coming in direct contact with an agent that might cause a disease or infectious process (e.g., exposure to hepatitis B virus might result in hepatitis B infection).
fecal–oral route: A mode of transmission of an infectious agent from person to person by putting something in the mouth that has been contaminated with infected stool (feces).
fibrosis: Scar tissue developed as a result of chronic infection and inflammation. The presence of fibrosis usually means infection has been active for several years.
genotype: The genetic makeup of the virus that describes the “family” to which the specific virus belongs.
hepatitis: Inflammation of the liver. The most common cause is infection with a hepatitis virus, but hepatitis can also be caused by other viruses, bacteria, parasites, and toxic reactions to drugs, alcohol, and chemicals.
hepatitis A: An inflammatory process of the liver caused by the hepatitis A virus.
hepatitis B: An inflammatory process of the liver caused by the hepatitis B virus.
hepatitis B core antibody: A protein that appears at the onset of symptoms in acute hepatitis B and persists for life. Its presence indicates previous or ongoing infection with the hepatitis B virus.
hepatitis B surface antibody: A protein that the immune system produces to attack hepatitis B virus. Its presence generally indicates recovery and immunity from the hepatitis B virus.
hepatitis B surface antigen: A serologic marker on the surface of the hepatitis B virus. It can be detected in high levels in serum during acute or chronic hepatitis.
hepatitis B virus DNA (deoxyribonucleic acid): A molecule that controls the manufacture of the hepatitis B virus. Its presence indicates active viral replication; high levels correlate with high rates of replication. Levels predict response to antiviral therapy.
hepatitis C: An inflammatory process of the liver caused by the hepatitis C virus.
hepatitis C virus RNA (ribonucleic acid): A fragment of the replicating hepatitis C virus. It can be detected using sophisticated tests to determine the level of the virus in serum.
hepatocellular carcinoma: The most common primary liver cancer.
high-risk behavior: Behavior that puts a person at risk of contracting hepatitis (e.g., sharing needles or drug paraphernalia; having multiple sex partners).
high-risk group: A group with an elevated risk of disease.
immune system: The complex system in the body responsible for fighting disease. It identifies foreign substances in the body (e.g., bacteria, viruses, fungi, parasites) and develops a defense against them known as the immune response. It produces protein molecules called antibodies to eliminate foreign organisms that invade the body.
immunity: Protection against a disease. There are two types of immunity: passive and active. Immunity is indicated by the presence of antibodies in the blood and can usually be determined with a laboratory test.
immunization: The process by which a person or animal becomes protected against a disease.
immunoglobulin: Proteins found in the blood that function as antibodies that fight infection.
infection: An invasion of an organism by a pathogen such as bacteria or viruses. Some infections lead to disease.
infectious: Capable of spreading disease. Also called communicable.
interferon: A group of proteins produced naturally by the cells of human bodies; interferon increases the resistance of surrounding cells to attacks by viruses.
jaundice: Yellow color in the skin, the mucous membranes, and the eyes.
lamivudine: A U.S. Food and Drug Administration-approved antiviral medication for treating chronic hepatitis B, taken orally.
liver enzyme: A protein that catalyzes chemical reactions needed for body functions. Levels of certain enzymes, such as alanine aminotransferase and aspartate aminotransferase, are higher when the liver is injured, as they leak into the bloodstream when the cell is inflamed, injured, or destroyed.
liver panel: Common blood tests that are used to evaluate liver function. Also called liver function tests.
medication-assisted treatment (MAT): Treatment for substance use disorders that uses medications such as methadone, buprenorphine, or naltrexone.
neutropenia: Low count of a type of white blood cell. Neutropenia has several causes including side effects of medications, viral infections, and autoimmune diseases.
pulmonary disease: A disease of the lungs.
ribavirin: A U.S. Food and Drug Administration-approved antiviral medication that improves the effectiveness of interferon in treating chronic hepatitis C, taken orally.
ribonucleic acid (RNA): Chemical found in the nucleus and cytoplasm of cells; plays an important role in protein synthesis and other chemical activities of the cell.
sustained virologic response (SVR): Achieving and sustaining a virus negative state for 6 months or longer after completing treatment for a virus, such as hepatitis C.
telaprevir: A U.S. Food and Drug Administration-approved medication for treating chronic hepatitis C, taken orally.
telbivudine: A U.S. Food and Drug Administration-approved medication for treating hepatitis B, taken orally.
tenofovir: A U.S. Food and Drug Administration-approved medication for treating hepatitis B, taken orally.
transmission: An incident in which an infectious agent is passed from one person to another.
viral load: Measurement of the amount of virus in the bloodstream.
virologic relapse: A return of the hepatitis C virus after antiviral treatment.
virus: An organism that multiplies within cells and causes diseases such as chickenpox, measles, mumps, rubella, pertussis, and hepatitis. It is not affected by antibiotics, the medications used to kill bacteria.