# References

Adirim, T., and N. Gupta. 1991. A national survey of State maternal and newborn drug testing and reporting policies. Public Health Reports. 106(3):292-296.
Alcohol and Drug Abuse Patient Records Regulations. 1991. (42 CFR Part 2), in Confidentiality: A Guide to the New Federal Regulations. Legal Action Center of the City of New York.
Alcohol, Drug Abuse, and Mental Health Administration. 1992. ADAMHA News.
Amaro, H., Zuckerman, B., and H. Cabral. 1989. Drug use among adolescent mothers: Profile of risk. Pediatrics. 84:144-151.
American Academy of Pediatrics, Committee on Substance Abuse. 1990. Drug-exposed infants. Pediatrics. 86(4):639-642. [pmid: 2216635].
American Academy of Pediatrics. 1991. Report of the Committee on Infectious Diseases.
American Academy of Pediatrics. 1992. Policy statement: Universal hepatitis B immunization. AAP News. February:13-15, 22.
The American Bar Association on Children and the Law. 1990. Drug-Exposed infants and their families: Coordinating responses of the legal, medical and child protection systems. Washington, DC: ABA.
American Civil Liberties Union Foundation. 1990.State-by-state case summary of criminal prosecutions against pregnant women and appendix of public health and public interest groups opposed to these prosecutions
American College of Obstetrics and Gynecology, Committee on Ethics. 1987. Patient choice: Maternal-fetal conflict (committee opinion). Washington, DC: American College of Obstetrics and Gynecology, October.
Anderson, S. 1989. The infant and toddler therapeutic shelter: A secure base. Zero to Three. 9(4):5-11.
Atkins, W.T. 1988. Cocaine: The drug of choice. In I.J. Chasnoff (Ed.), Drugs, alcohol, pregnancy and parenting. Boston: Kluwer Academic Publishers, pp. 91-96.
Ballard, J.L., Kazmaier, K., and M. Driver. 1977. A simplified assessment of gestational age, abstracted. Pediatric Research. 11:374.
Ballard, J.F., Novak, K.K., and M. Driver. 1979. A simplified score for assessment of fetal maturation of newly born infants. Journal of Pediatrics. 95:769-774.
Bandstra, E.S. 1991. Introduction. Seminars in Perinatology. 15(4):263-264.
Bandstra, E.S., and G. Burkett. 1991. Maternal-fetal and neonatal effects of in utero cocaine exposure. Seminars in Perinatology. 15(4):288-301. [pmid: 1948140].
Bauchner, H., and Zuckerman, B. 1990. Cocaine, SIDS and home monitoring. Journal of Pediatrics. 117:904-906.
Beth Israel Hospital, N.Y. N.d. Forensic urine toxicology testing and procedures.
Beth Israel Hospital, N.Y. N.d. Maternal urine toxicology policy.
Beth Israel Hospital, N.Y. N.d. Policy related to neonatal urine toxicologies.
Beth Israel Hospital, N.Y. N.d. Procedure for collection of urine toxicology specimens.
Brazelton, T.B. 1984. Neonatal behavioral assessment scale, second edition Philadelphia: Lippincott.
Broekhuizen, F.F., Utrie, J., and C. Van Mullen. 1992. Drug use or inadequate prenatal care? Adverse pregnancy outcome in an urban setting. American Journal of Obstetrics and Gynecology. 166(6):1747-1756. [pmid: 1615983].
Brown, R.T., Coles, C.D., Smith, I.E., Platzman, K.A., Silverstein, J., Erickson, S., and A. Falek. 1991. Effects of prenatal alcohol exposure at school age. II. Attention and behavior. Neurotoxicology and Teratology. 13:369-376.
Burstein, Y., Giardina, P.J.V., Rausen, A.R., Kandall, S.R., Siljestrom, K., and C.M. Peterson. 1979. Thrombocytosis and increased circulating platelet aggregates in newborn infants of polydrug users. Journal of Pediatrics. 94(6):895-899.
Bussiere, A., and C. Shauffer. 1990. The little prisoners. Youth Law News. 11(1):22-26.
California Legislature. 1989. The 1980-90 budget: Perspectives and issues - Substance-exposed infants.
California Senate Office of Research. 1990. California's drug-exposed babies. Undiscovered, unreported, and underserved: A county-by-county survey. Sacramento.
Center for Substance Abuse Treatment. (In draft). Treatment improvement protocol statement. Pregnant, substance-using women.
Chasnoff, I.J. ed. 1986. Drug use in pregnancy: Mother and child.
Chasnoff, I.J. ed. 1988. Drugs, alcohol, pregnancy and parenting.
Chasnoff, I.J. 1989. Cocaine and pregnancy: Implications for the child (editorial). Western Journal of Medicine. 150(4):456-458.
Chasnoff, I.J. 1989a. Cocaine, pregnancy, and the neonate. Women and Health. 15(3):23-35.
Chasnoff, I.J. 1989b. Cocaine: Two year follow-up of infants. Paper presented at the National Association for Perinatal Addiction Research and Education Conference. Miami, FL, December.
Chasnoff, I.J. 1989c. Drug use and women: establishing a standard of care. Annals of the New York Academy of Science. 562:208-210.
Chasnoff, I.J. 1991. Drugs, alcohol, pregnancy, and the neonate: Pay now or pay later. Journal of the American Medical Association. 226(11):1567-1568.
Chasnoff, I.J., Burns K.A., and W.J. Burns. 1987. Cocaine use in pregnancy: Perinatal morbidity and mortality. Neurotoxicology and Teratology. 9(4):291-293. [pmid: 3683346].
Chasnoff, I.J., and D.R. Griffith. 1989. Cocaine: Clinical studies of pregnancy and the newborn. Annals of the New York Academy of Science 260.
Chasnoff, I.J., Griffith, D.R., Freier, C., and J. Murray. 1992. Cocaine/polydrug use in pregnancy: two-year follow-up. Pediatrics. 89(2):284-289. [pmid: 1370867].
Chasnoff, I.J., Griffith, D.R., MacGregor, S., Dirkes, K., and K.A. Burns. 1989. Temporal patterns of cocaine use in pregnancy: Perinatal outcome. Journal of the American Medical Association. 261(12):1741-1744.
Chasnoff, I.J., Hatcher, R., and W.J. Burns. 1980. Early growth patterns of methadone-addicted infants. American Journal of Diseases of Children. 134:1049-1051.
Chasnoff, I.J., Hunt, C.E., Kletter, R., and D. Kaplan. 1989. Prenatal cocaine exposure is associated with respiratory pattern abnormalities. American Journal of Diseases of Children. 143:583-587.
Chasnoff, I.J., Landress, H.J., and M.E. Barrett. 1990. The prevalence of illicit drug or alcohol use during pregnancy and discrepancies in mandatory reporting in Pinellas County, Florida. New England Journal of Medicine. 332:1202-1206.
Chasnoff, I.J., Lewis, D.W., Griffith, D.R., and S. Willey. 1989. Cocaine and pregnancy: Clinical and toxicological implications for the neonate. Clinical Chemistry. 35(7):1276-1278. [pmid: 2758571].
Chavkin, W. 1990. Drug addiction and pregnancy: Policy crossroads. American Journal of Public Health. 80(4):483-487. [pmid: 2180329].
Chavkin, W., Driver, C.R., and P. Forman, 1989. The crisis in New York City's perinatal services. New York State Journal of Medicine. 89(12):658-663. [pmid: 2687734].
Chavkin, W., and S.R. Kandall. 1990. Between a rock and a hard place - Perinatal drug-abuse. Pediatrics. 85(2):223-225. [pmid: 2296513].
Cherukuri, R., Minkoff, H., Feldman, J., Parekh A., and L. Glass. 1988. A cohort study of alkaloidal cocaine ("crack") in pregnancy. American Journal of Obstetrics and Gynecology. 72:147-151.
Child Welfare League of America. 1992. Children at the front: A different view of the war on alcohol and drugs.
Chisum, G.M. Adams C., Eyler, F.D., and M. Behnke. 1990. Nursing intervention with mothers who are substance abusers. Journal of Perinatal and Neonatal Nursing. 3(4).
Cole, H. 1990. Legal interventions during pregnancy. Court-ordered medical treatments and legal penalties for potentially harmful behavior by pregnant women. Journal of the American Medical Association. 264(20):2663-2670.
Coles, C.D., Brown, R.T., Smith, I.E., Platzman, K.A., Erickson, S., and A. Falek. 1991. Effects of prenatal alcohol exposure at school age. I. Physical and cognitive development. Neurotoxicology and Teratology. 14:357-367.
Coles, C.D., and K.A. Platzman. Fetal alcohol effects in preschool children: Research, prevention and intervention. In OSAP Monograph 11: Identifying the needs of drug-affected children: Public policy issues. Washington, D.C.: U.S. DHHS. 59-86.
Coles, C.D., Platzman, K.A., Smith, I.E., James, M.E., and A. Falek. 1992. Effects of cocaine and alcohol use in pregnancy on neonatal growth and neurobehavioral status. Neurotoxicology and Teratology. 14:23-33.
Colorado Perinatal Care Council. 1991. A protocol for managing prenatal drug abuse.
Committee on Substance Abuse. 1990. Drug-exposed infants. Pediatrics. 86(4):639-642. [pmid: 2216635].
Connolly, W.B., and A.B. Marshall. 1990. Drug addiction, pregnancy and childbirth: Legal issues for the medical and social services communities. In J. Larsen (Ed.), Drug-exposed infants and their families: Coordinating responses of the legal, medical and child protection system (pp. 31-50). Washington, DC: American Bar Association.
Cooper, J.R. 1989. Methadone treatment and acquired immunodeficiency syndrome. Journal of the American Medical Association. 262(12):1664-1668.
County of Los Angeles Department of Children's Services. 1989. Protect children, strengthen families.
Day, N.L., and G.A. Richardson. 1991. Prenatal alcohol exposure: A continuum of effects. Seminars in Perinatology. 15(4):271-279. [pmid: 1948138].
Deren, S. 1986. Children of substance abusers: A review of the literature. Journal of Substance Abuse Treatment. 3:77-94.
Dering, Doering P.L., Davidson, C.L., LaFauce, L., et al. 1989. Effects of cocaine on the human fetus: A review of clinical studies. Drug Intelligence and Clinical Pharmacology, The Annals of Pharmacotherapy. 23:639-645.
Dicker, M., and E.A. Leighton. 1991. Trends in diagnosed drug problems among newborns: United States, 1979-1987. Drug and Alcohol Dependence. 28(August):151-165.
Dixon, S.D. 1989. Effects of transplacental exposure to cocaine and methamphetamine on the neonate. Western Journal of Medicine. 150(4):436-442.
Dixon, S.D., and R. Bejar. 1989. Echoencephalographic findings in neonates associated with maternal cocaine and methamphetamine use: Incidence and clinical correlates. Journal of Pediatrics. 115:770-778.
Dixon, S.D., Bresnahan, K., and B. Zuckerman. 1990. Cocaine babies: meeting the challenge of management. Contemporary Pediatrics. June:70-92.
Doberczak, T.M., Kandall, S.R., and I. Wilets. 1991. Neonatal opiate abstinence syndrome in term and preterm infants. Journal of Pediatrics. 118:933-937.
Doberczak, T.M., Shazner,Shanzer, S., Cutler, R., Senie, R.T., Loucopoulos, J.A., and S.R. Kandall. 1988. One year follow-up of infants with abstinence-associated seizures. Archives of Neurology. 45:649-653.
Doberczak, T.M., Shanzer, S., Senie, R.T., and S.R. Kandall. 1988. Neonatal neurologic and electroencephalographic effects of intrauterine cocaine exposure. Journal of Pediatrics. 113:354-358.
Doberczak, T.M., Thornton, J.C., Bernstein, J., and S.R. Kandall. 1987. Impact of maternal drug dependency on birth weight and head circumference of offspring. American Journal of Diseases of Children. 141:1163-1167.
Dombrowski, M.P., and R. Sokol. 1990. Cocaine and abruption. Contemporary OB/GYN. April:13-19.
Driscoll, C.D., Streissguth, A., and E. Riley. 1990. Prenatal alcohol exposure: Comparability of effects in humans and animal models. Neurotoxicology and Teratology. 12(3):231-237. [pmid: 2196422].
Dunn-Malhotra, E. 1990. Medicaid waivers promising for some drug-exposed children; Don't help most. Youth Law News. 11(1):27-31.
Dunst, C., Trivette, C., and A. Deal. 1988. Enabling and Empowering Families.
Emmelkamp, P.M. 1988. Drug addiction and parental rearing style: A controlled study. The International Journal of the Addictions. 23(2):207-216. [pmid: 3366496].
English, A. 1990. Prenatal drug exposure: Grounds for mandatory child abuse reports?. Youth Law News. 11(1):3-8.
English, A., and M. Henry. 1990. Legal issues affecting drug-exposed infants. Youth Law News. 11(1):1-2.
Feig, L. 1991. Drug-exposed infants: Service needs and policy questions. Report prepared for the Office of the Assistant Secretary for Policy and Evaluation, U.S. Department of Health and Human Serices, January.
Fink, J.R. 1990. Reported effects of crack and cocaine on infants. Youth Law News. 11(1):37-39.
Finnegan, L.P., ed. 1979. Drug Dependence in Pregnancy: Clinical Management of Mother and Child.
Finnegan, L.P. 1979. In utero opiate dependence and Sudden Infant Death Syndrome. Clinical Perinatology. 6:63-120.
Finnegan, L.P. 1986. Neonatal abstinence syndrome: Assessment and pharmacotherapy. In Neonatal Therapy: An Update, ed. Rubatelli F.F., and B. Granatt. Elsevier Sciences Publishers B.V.
Finnegan, L.P. 1991. Perinatal substance abuse: Comments and perspectives. Seminars in Perinatology. 15(4):331-339. [pmid: 1948145].
Finnegan, L.P., and S.M. Ehlirch. 1990. Maternal drug abuse during pregnancy: Evaluation and pharmacotherapy for neonatal abstinence. In Modern Methods In Pharmacology, Volume 6, Testing and Evaluation of Drugs of Abuse. Willey-Liss, Inc., pp. 255-263.
Finnegan, L.P., Hagan, T., and K.A. Kaltenbach. 1991. Scientific foundation of clinical practice: Opiate use in pregnant women. Bulletin of the New York Academy of Medicine. 67 (3):223-239.
Finnegan, L.P., and K. Kaltenbach. 1992. Neonatal Abstinence Syndrome. In Primary Pediatric Care, Edition 2, Hoekelman and Nelson eds. St. Louis: Mosby Yearbook, Inc., pp. 1367-1378.
Finnegan, L.P., Kron, R.E., Connaughton, J.F., and J. P. Emich. 1975. A scoring system for evaluation and treatment of the neonatal abstinence system: A new clinical and research tool. In Basic and Therapeutic Aspects of Perinatal Pharmacology, ed. Morselli, P.L., Garattini, S., and F. Sereni. New York: Raven Press, 139-155.
Frank, D.A., Bauchner, H., Parker, S., et al. 1990. Neonatal body proportionality and body composition after in utero exposure to cocaine and marijuana. Journal of Pediatrics. 117:622-626.
Frank, D.A., Zuckerman, B.S., H. Amaro, et al. 1988. Cocaine use during pregnancy: Prevalence and correlates. Pediatrics. 82:888-895.
Freier, M.C., Griffith, D.R., and I.J. Chasnoff. 1991. In utero drug exposure: Developmental follow-up and maternal-infant interaction. Seminars in Perinatology. 15(4):310-316. [pmid: 1948142].
Fried, P.A. 1991. Marijuana use during pregnancy: Consequences for the offspring. Seminars in Perinatology. 15(4):280-287. [pmid: 1948139].
Fried, P.A., Watkinson, B., Dillon, R.F., and C.S. Dullberg. 1990. 1987. Neonatal neurological status in a low-risk population after prenatal exposure to cigarettes, marijuana, and alcohol. Journal of Developmental Behavioral Pediatrics. 8(6):318-26.
Fulroth, R., Phillips, B., and D.J. Durrand. 1989. Perinatal outcome of infants exposed to cocaine and/or heroin in utero. American Journal of Diseases of Children. 143:905-910.
Gardner, S.L., Garland, K.R., Merenstein, S.L., and G.B. Merenstein. 1989. The neonate and the environment: Impact on development. In Handbook of Neonatal Intensive Care, 2nd Edition. Merenstein G.B., and S. L. Gardner eds. St. Louis: C.V. Mosby, pp. 628-675.
Gomby, D.S., and P.H. Shiono. 1991. Estimating the number of substance-exposed infants. The Future of Children. 1(1):17-25.
Graham, K., Koren, G.I., Klein, J., Schneiderman, J., and M. Greenwald. 1989. Determination of gestational cocaine exposure by hair analysis. Journal of the American Medical Association. 262(23):3328-3330.
Griffith, D.R. 1988. The effects of perinatal cocaine exposure on infant neurobehavior and early maternal-infant interactions. In I.J. Chasnoff ed. Drugs, alcohol, pregnancy and parenting. Hingham, MA: Kluwer Academic Publishers, pp. 105-114.
Griffith, D.R. 1990. Developmental follow-up of cocaine-exposed infants to three years. Paper presented at the International Society for Infant Studies Conference, Montreal.
Grimm, B. 1990. Drug-exposed infants pose new problems for juvenile courts. Youth Law News. 11(1):9-14.
Harper, R.G., Solish, G.I., Puron, H.M., Sang, E., and W.C. Penepinto. 1974. The effects of methadone treatment program upon pregnant heroin addicts and their newborn infants. Pediatrics. 54(3):300-305. [pmid: 4416175].
Harper, R.G., Solish, G., Feingold, E., Gersten-Wolf, N.B., and M.M. Sokal. 1977. Maternal ingested methadone, body fluid methadone, and the neonatal withdrawal syndrome. American Journal of Obstetrics and Gynecology. 129:417.
Heier, L.A., C.R. Carpanzano, J. Mast, P.W. Brill, P. Winchester, and M.D.F. Deck. 1991a. Maternal cocaine abuse: The spectrum of radiologic abnormalities in the neonatal CNS. American Journal of Neuroradiology. 12 (September/ October):951-956.
Heier, L.A., Carpanzano, C.R., Mast, J., Brill, P.W., Winchester, P., and M.D.F. Deck. 1991b. Maternal cocaine abuse: The spectrum of radiologic abnormalities in the neonatal CNS. American Journal of Roentgeneology. 157(November):1105-1110.
Herzlinger, R.A., Kandall, S.R., and H.G. Vaughan. 1977. Neonatal seizures associated with narcotic withdrawal. . Journal of Pediatrics. 91(4):638-641.
Hoegerman, G., and C. Wilson. 1990. Drug-exposed neonates. Western Journal of Medicine 152(5):559-564.
Horowitz, R. 1990. Perinatal substance abuse: A coordinated public health and child welfare response. Children Today. (July-August):8-12.
Howard, J., Rodning, C., and V. Kropenske. 1989. The development of young children of substance-abusing parents: Insights from seven years of intervention and research. Zero to Three. 9(5):8-12.
Hoyme, H.E., Jones, K.L., Dixon, S.D., Jewett, T., Hanson, J.W., Robinson, L.K., Msali, M.E., and J.E. Allanson. 1990. Prenatal cocaine exposure and fetal vascular disruption. . Pediatrics. 85(5):743-747. [pmid: 2330234].
Hoyseth, K., and P. Jones. 1989. Minireview: Ethanol induced teratogenesis: Characterization, mechanisms and diagnostic approaches. Life Sciences. 44:643-649.
Hutchnings, D.E. ed. 1988. Prenatal abuse of licit and illicit drugs.
Jameson, W., and N. Halfon. 1990. Treatment programs for drug-dependent women and their children. Youth Law News. 11(1):20-21.
Janke, J. 1990. Prenatal cocaine use: Effects on perinatal outcome. . Journal of Nurse-Midwifery. 35(2):74-77. [pmid: 2319338].
Jessup, M. 1990. The treatment of perinatal addiction. Identification, intervention, and advocacy. Western Journal of Medicine. 152(5):553-558.
Jessup, M., and J. Green. 1987. Treatment of the pregnant alcohol-dependent woman. Journal of Psychoactive Drugs. 19(2):193-203. [pmid: 3612385].
Jhaveri, R.C., Glass, L., Evans, H.E., Dube, S.K., Rosenfeld, W., Khan, F., Salazar, J.D., and O. Chandavasu. 1980. Effects of methadone on thyroid function in mother, fetus, and newborn. Pediatrics. 65(3):557-561. [pmid: 7189054].
Johnsen, D.E. 1986. The creation of fetal rights: Conflicts with women's Constitutional rights to liberty, privacy, and equal protection. Yale Law Journal. 95:599.
Johnson, E.M., and E. Hutchins. 1990. Pregnant and post-partum women and their infants. Office for Substance Abuse Prevention Special Report #1. Available from Division of Demonstrations and Evaluation, OSAP, Rockwall Building II, 5515 Security Lane, Rockville, MD 20857.
Jones, C. L., and R.E. Lopez. 1988. Direct and indirect effects on the infant of maternal drug abuse.
Juvenile Welfare Board of Pinellas County. 1990. A challenge for all: Recommendations for a community-wide response to drug-involved infants and mothers.
Kaltenbach, K., and L.P. Finnegan. 1984. Developmental outcome of children born to methadone maintained women: A review of longitudinal studies. Neurobehavioral Toxicology and Teratology. 6(4):271-275. [pmid: 6392916].
Kaltenbach, K., and L.P. Finnegan. 1987. Perinatal and developmental outcome of infants exposed to methadone in utero. Neurotoxicology and Teratology. 9:311-313.
Kaltenbach, K., and L.P. Finnegan. 1988. The influence of the neonatal abstinence syndrome on mother-infant interaction. In The Child and his Family: Perilous Development: Child Raising and Identity Formation under Stress. Vol 8. Anthony E.J., and C. Chiland eds. Wiley-Interscience.
Kaltenbach, K., and L.P. Finnegan. 1989. Children exposed to methadone in utero. Annals of the New York Academy of Sciences. 562:360-362.
Kaltenbach, K., and L.P. Finnegan. 1992. Prenatal opiate exposure: Physical, neurobehavioral, and developmental effects. In. Development of the Central Nervous System: Effects of Alcohol and Opiates. . Wiley-Liss, Inc., pp. 37-46.
Kaltenbach, K., Graziani, L.J., and L.P. Finnegan. 1979. Methadone exposure in utero: Developmental status at one and two years of age. Pharmacology, Biochemistry, and Behavior. II:Supp. 15-17.
Kandall, S.R. 1991a. Drug Abuse. In Fetal and Neonatal Effects of Maternal Disease. Sweet and Brown, eds. St. Louis: Mosby-Year Book, pp. 401-413.
Kandall, S.R. 1991b. Perinatal effects of cocaine and amphetamine use during pregnancy. Bulletin of the New York Academy of Medicine. 67(3):240-255. [pmid: 1868276].
Kandall, S.R., Albin, S., Lowinson, J., Berle, B., Eidelman, A., and L.M. Gartner. 1976. Differential effects of maternal heroin and methadone use on birthweight. Pediatrics. 58:681-685.
Kandall, S.R., Doberczak, T.M., Mauer, K.R., Strashun, R.H., and D.C. Korts. 1983. Opiate v CNS depressant therapy in neonatal drug abstinence syndrome. American Journal of Diseases of Children. 137:378-382.
Kandall, S.R., and J. Gaines. 1991. Maternal substance use and subsequent sudden infant death syndrome (SIDS) in offspring. Neurotoxicology and Teratology. 13(2):235-240. [pmid: 2046641].
Kandall, S.R., and L.M. Gartner. 1974. Late presentation of drug withdrawal symptoms in newborns. American Journal of the Diseases of Children. 127(January):58-61.
Kandall, S.R. et al. 1993. In press. Article on sudden infant death syndrome in infants of substance-using mothers. Journal of Pediatrics.
Kaye, K., Elkind, L., Goldberg, D., and A. Tytun. 1989. Birth outcomes for infants of drug abusing mothers. New York State Journal of Medicine. May.
Kennard, M. J. 1990. Cocaine use during pregnancy: Fetal and neonatal effects. Journal of Perinatal and Neonatal Nursing. 3(4).
Khalsa, J.H., and J. Gfoerer. Gfroerer. 1991. Epidemiology and health consequences of drug abuse among pregnant women. Seminars in Perinatology. 15(4):265-270. [pmid: 1948137].
Koren, G., Graham, K., Shear, K., and T. Einarsn. 1989. Bias against the null hypothesis: The reproductive hazards of cocaine. Lancet. 2(8677):1440-1442. [pmid: 2574369].
Kronstadt, D. 1989. Pregnancy and cocaine addiction: An overview of impact and treatment (report from the Drug-Free Pregnancy Project, Center for Child and Family Studies). San Francisco: Far West Laboratory for Educational Research and Development.
Kronstadt, D. 1991. Complex developmental issues of prenatal drug exposure. The Future of Children. 1(1):36-46.
Kumpfer, K.L. 1991. Treatment programs for drug-abusing women. The Future of Children. 1(1):150-60.
Larsen, J. ed. 1990. Drug-exposed infants and their families: Coordinating responses of the legal, medical and child protection system. Washington, DC: American Bar Association.
Larson, C. 1991. Overview of state legislative and judicial responses. The Future of Children. 1(1):72-84.
Legal Action Center of the City of New York. 1991. Confidentiality: A Guide to the New Federal Regulations.
Lockwood, S.E. 1990. What's known - and what's not known about drug-exposed infants. Youth Law News. 11(1):15-19.
Los Angeles Unified School District. 1989. Today's challenge: Teaching strategies for working with youth and children prenatally exposed to drugs/alcohol (pamphlet). Los Angeles.
Lubchenco, L.O., Hansman, C., and E. Boyd. 1966. Intrauterine growths in length and head circumference as estimated for live births at gestational ages from 26-42 weeks. Pediatrics. 37:403-408.
MacDonald, M.G., Rifai, N., Morales, A., et al. 1990. Maternal drug abuse in an inner city NICU. Pediatric Research. 27(4/Part 2):248A.
MacGregor, S.N., Keith, L.G., Bachiacha, J.A., and I.J. Chasnoff, 1989. Cocaine abuse during pregnancy: Correlation between prenatal care and perinatal outcome. Obstetrics and Gynecology. 74(6):822-885.
MacGregor, S.N., Keith, L.G., Chasnoff, I.J., Rosner, M.A., Chisum, G.M., Shaw, P., and J.P. Minogue. 1987. Cocaine use during pregnancy: Adverse perinatal outcome. American Journal of Obstetrics and Gynecology. 157:686-690.
Mayes, L.C., Granger, R.H., Bornstein, M.H., and B. Zuckerman. 1992. The problem of prenatal cocaine exposure: A rush to judgment. Journal of the American Medical Association. 267(3):406-408.
McCullugh, C.B. 1991. The child welfare response. The Future of Children. 1(1):61-71.
McNulty, M. 1990. Pregnancy policy: Implications of criminalizing fetal abuse. Youth Law News. 11(1):33-36.
Miller, G. 1989. Addicted infants and their mothers. Zero to Three. 9(5):20-23.
Murray, T.H. 1991. Prenatal drug exposure: Ethical issues. The Future of Children. 1(1):105-112.
National Black Child Development Institute. 1989. Who will care when parents can't?.
National Coalition on Alcoholic and Drug-Dependent Women and Their Children. 1990. State legislative and policy proposals.
National Commission on Child Welfare and Family Preservation. 1990. A commitment to change.
National Council of Juvenile and Family Court Judges. 1991. Protocol for Decision-Making in Drug-Related Dependency Cases.
The New York Times, The no-parent child (editorial). December 24, 1989,. E10.
The New York Times, Mothers, babies and crack (editorial). May 14, 1989,. E22.
North American Commission on Chemical Dependency and Child Welfare. N.d. Glossary of Terms.
Oro, A.S., and S.D. Dixon. 1987. Perinatal cocaine and methamphetamine exposure: Maternal and neonatal correlates. Journal of Pediatrics. 111:571-578.
Ostrea, E.M., and M. Brady. 1990. Are perinatal complications different with the abuse of cocaine, heroin or cannabinoid during pregnancy?. Pediatric Research. 27(4/Part 2):219A.
Ostrea, E.M., Brady, M., Gause, S., Raymundo, A.L., and M. Stevens. 1992. Drug screening of newborns by meconium analysis: A large-scale, prospective, epidemiologic study. Pediatrics. 89(1):107-113. [pmid: 1727992].
Ostrea, E.M., Brady, M.J., Gause, S., et al. 1991. Prevalence of illicit drug use during pregnancy as determined by meconium analysis: A study of 3,010 cases. Pediatric Research. 29:229.
Ostrea, E.M., Brady, M.J., Parks, P.M., Asenio, D.C., and A. Naluz. 1989. Drug screening of meconium in infants of drug-dependent mothers: An alternative to urine testing. Journal of Pediatrics. 115:474-477.
Petrantoni, M., and R.A. Knuppel. 1991. Clinical Perinatology. 18(1):93-111.
Phares, V. 1992. Where's Poppa? The relative lack of attention to the role of fathers in child and adolescent psychopathology. American Psychologist. 47(5):656-664.
Phibbs, C.S. 1991. The economic implications of prenatal substance exposure. The Future of Children. 1(1):113-120.
Phibbs, C.S., Bateman, D.A., and R.M. Schwartz. 1991. The neonatal costs of maternal cocaine use. Journal of the American Medical Association. 226(11):1521-1526.
Prober, C.G., and A.A. Gershon. 1991. Medical management of newborns and infants born to human immunodeficiency virus-seropositive mothers. Pediatric Infectious Disease Journal. 10:684-95.
Regan, D.O., Ehrlich, S.M., and L.P. Finnegan. 1987. Infants of drug addicts: At risk for child abuse, neglect, and placement in foster care. Neurotoxicology and Teratology. 9(4):315-319. [pmid: 3683350].
Rieder, B.A. 1990. Perinatal substance abuse and public health nursing intervention. Children Today. 19(4):33-35. [pmid: 2261809].
Roberts, D.E. 1990. Drug addicted women who have babies. Trial. April:56-61.
Rodning, C., Beckwith, L., and J. Howard. 1990. Attachment in play in prenatal drug exposure. Development and Psychopathology. 1:277-289.
Rosen, T.S., and C.E. Pippenger. 1976. Pharmacologic observations on neonatal withdrawal syndrome. Journal of Pediatrics. 88:1044-1048.
Ryan, L., Ehrlich, S., and L. Finnegan. 1987. Cocaine abuse in pregnancy: Effects on the fetus and newborn. Neurotoxicology and Teratology. 9(4):295-299. [pmid: 3683347].
Schneider, J.W., Griffith, D.R., and I.J. Chasnoff. 1989. Infants exposed to cocaine in utero: Implications for developmental assessment and intervention. Infants and Young Children. 2(1):25-36.
Scott, K.G., Urbano, J.C., and C.A. Boussy. 1991. Long-term psychoeducational outcome of prenatal substance exposure. Seminars in Perinatology. 15(4):317-323. [pmid: 1948143].
Silverman, S. 1989. Combinations of drugs taken by pregnant women add to problems in determining fetal damage [news]. Journal of the American Medical Association. 261(12):1964.
Smith, I.E. 1992. An ecological perspective: The impact of culture and social environment on drug-exposed children. In. OSAP Monograph 11: Identifying the needs of drug-affected children: Public policy issues. Washington, D.C.: U.S. DHHS. 93-108.
Smith, I.E., and C.D. Coles. 1991. Multilevel intervention for prevention of fetal alcohol syndrome and effects of prenatal alcohol exposure. In. Recent developments in alcoholism: Treatment issues, Volume IX. , Galanter, M. ed. pp. 165-180.
Sokol, R.J., Miller, S., and G. Reed. Martier, D.D., J.W. Ager. 1989. The T-ACE questions: Practical prenatal detection of risk-drinking. American Journal of Obstetrics and Gynecology. 160(4):863-870. [pmid: 2712118].
Soman, L.A., Klee, L., and N. Halfon. 1989. Meeting the health needs of children in foster care: Implementing national standards in California - A report from the task force on foster care. Oakland, CA: Center for the Vulnerable Child, Children's Hospital of Oakland.
Southern Association for Children Under Six. 1991. Prenatal cocaine exposure: The South looks for answers.
Starr, K. 1991. Interdepartmental consultation and continuity of care for chemically dependent pregnant women - a team approach. Substance Abuse. 12(4):173-176.
Streissguth, A.P., Aase, J.M., Clarren, S.K., Randels, S.P., LaDue, R.A., and D.F. Smith. 1991. Fetal alcohol syndrome in adolescents and adults. Journal of the American Medical Association. 265(15):1961-1967.
Suguihara, C., and E. Bancalari. 1991. Substance abuse during pregnancy: Effects on respiratory function in the infant. Seminars in Perinatology. 15(4):302-309. [pmid: 1948141].
Sullivan, K.R. 1990. Maternal implications of cocaine use during pregnancy. Journal of Perinatal and Neonatal Nursing. 3(4).
Title, B., and N. St. Claire. 1989. Promoting the health and development of drug-exposed infants through a comprehensive clinic model. Zero to Three. 9(5):18-20.
Treaster, J.B. 1991. Plan lets addicted mothers take their newborns home. The New York Times. Thursday, September 19.
U.S. General Accounting Office. 1990. Drug-Exposed Infants: A Generation at Risk.
U.S. House of Representatives. 1989. Born hooked: Confronting the impact of perinatal substance abuse.
U.S. House of Representatives. 1990. Beyond the stereotypes: Women, addiction, and perinatal substance abuse.
U.S. House of Representatives. 1990. Getting straight: Overcoming treatment barriers for addicted women and their children.
U.S. House of Representatives. 1990. Law and policy affecting addicted women and their children.
U.S. House of Representatives. 1990. Victims of drug abuse.
U.S. House of Representatives, Ways and Means Committee. 1990. The enemy within: Crack-cocaine and America's families.
U.S. Senate, 1990. Falling through the crack: The impact of drug-exposed children on the child welfare system. Hearing before the Subcommittee on Children, Families, Drugs and Alcohol, Senate Labor and Human Resources Committee. Washington, DC: U.S. Government Printing Office, March 8.
Vandenberg, K. 1989. The impact of drug exposure on the development of infants. Paper presented at the Conference on Drug-Free Pregnancy, San Francisco.
Walker, C., Zangrillo, P., and J. Smith. 1991. Parental drug abuse and African American Children in foster care: Issues and study findings. Washington, DC: National Black Child Development Institute.
Weston, D.R., Ivins, B., Zuckerman, B., Jones, C., and R. Lopez. 1989. Drug-exposed babies: Research and clinical issues. Zero to Three. 9(5):1-7.
White, D.M. N.D. Promoting optimal solutions to substance abuse and exposure.
Wilson, G.S., Desmond, M.M., and W.M. Verniaud. 1973. Early development of infants of heroin-addicted mothers. American Journal of the Diseases of Children. 126 (October):457-462.
Zeitel, L., Bauer, T.A., and P. Brooks. 1991. Infants at Risk: Solutions Within Our Reach. New York: Greater New York March of Dimes/United Hospital Fund of New York.
Zuckerman, B. 1991. Drug-exposed infants: Understanding the medical risk. The Future of Children. 1(1):26-35.
Zuckerman, B., Amaro, H., and H. Cabral. 1989. Validity of self-reporting of marijuana and cocaine use among pregnant adolescents. Journal of Pediatrics. . 115(5 Part 1):812-815.
Zuckerman, B., and D.A. Frank. 1992. "Crack" kids: Not broken. Pediatrics. 89 (2):337-339.
Zuckerman, B., Frank, D.A., Hingson, R., et al. 1989. Effects of maternal marijuana and cocaine use on fetal growth. New England Journal of Medicine. 320(12):762-768.
Zuckerman, B., Frank, D., Parker, S., Bauchner, H., et al. 1989. Effects of maternal marijuana and cocaine use on fetal growth - reply. New England Journal of Medicine. 321(14):979.
Zuckerman, B., Parker, S., Hingson, R., et al. 1986. Maternal psychoactive substance use and its effect on the neonate. In A. Milunsky, E.A. Friedman, and L. Gluck (Eds.), Advances in Prenatal Medicine. New York: Plenum Press.