# Consensus Panel

- Mehmur Abedin, M.D.
- Assistant Professor of Pediatrics & Child Health
- Chief of Neonatology
- D.C. General Hospital
- Washington, D.C.

- Emmalee Bandstra, M.D.
- University of Miami
- Department of Pediatrics
- Division of Neonatology
- Miami, Florida

- Andrea G. Barthwell, M.D.
- Medical Director
- Interventions
- Chicago, Illinois

- Donna H. Caum
- Program Consultant
- Bureau of Alcohol and Drug Abuse Services
- State of Tennessee
- Department of Health
- Nashville, Tennessee

- Janet Chandler, Ph.D.
- Clinical Psychologist
- NAPARE
- Chicago, Illinois

- Tatiana Doberczek, M.D.
- Assistant Chief
- Division of Neonatology
- Beth Israel Street
- Medical Center
- New York, New York

- Roselyn Epps, M.D., M.P.H.
- National Medical Association
- Professor of Pediatrics & Child Health
- Howard University, College of Medicine
- Bethesda, Maryland

- Alan Fleischman, M.D.
- Director
- Division of Neonatology
- Professor of Pediatrics
- Albert Einstein Hospital
- Bronx, New York

- Sandra Gardner, R.N., P.N.P.
- Director, Professional Outreach Consultation
- Aurora, Colorado

- Robert H. Horowitz, J.D.
- Associate Director
- American Bar Association Center on Children and the Law
- American Bar Association
- Washington, D.C.

- Karol Kaltenbach, Ph.D.
- Director
- Family Center/TJU
- Philadelphia, Pennsylvania

- Stephen Kandall, M.D.
- Chief, Division of Neonatology
- Beth Israel Street Medical Center
- New York, New York

- Margot Kaplan-Sanoff, Ed. D.
- Associate Professor, Pediatrics
- Boston University School of Medicine
- Director, Steps for Kids
- Outreach Training Project
- Talbot Building
- Boston City Hospital
- Boston, Massachusetts

- Hubert Kelly, D.S.W.
- Social Work Consultant
- Oakton, Virginia

- Dennis Nalty, Ph.D.
- Director
- Analysis and Policy
- Development (Scatter Project)
- South Carolina Commission on Alcohol and Drug Abuse
- Columbia, South Carolina

- Christine D. Olson
- Director, Treatment Programs
- Colorado Department of Health
- Alcohol and Drug Abuse Division
- Denver, Colorado

- Beth Wasson
- Executive Director
- Triumph Treatment Services
- Yakima, Washington