# Chapter 2 - Medical Management of The Drug-Exposed Infant

Medical management of the drug-exposed infant has emerged in recent years as a major challenge to health care professionals. This chapter presents the TIP consensus panel's recommendations and guidelines for diagnosis of in utero drug exposure, medical assessment of the neonate, effects of exposure to different types of drugs, guidelines for appropriate treatment, promotion of positive parent-infant interaction, and discharge criteria and instructions. As a foundation for its guidelines in these specific areas, the consensus panel recommends the following:

- Surveillance - Clinicians should be aware of shifting local trends due to user preferences and street market availability of particular drugs within the community. Networking with local emergency and trauma services, drug treatment providers, social service agencies, and the criminal justice system provides neonatal caregivers with an opportunity for community surveillance. However, each nursery also should monitor the changing patterns of drug exposure in its newborn population. Further, the quality of data on drug abuse patterns obtained from maternal histories or anonymous toxicology screens should be continually monitored.
- Preconception - Ideally, obstetricians, family practitioners, midwives, family planning clinicians, and other clinicians providing health care to women of childbearing age should provide counseling regarding abstinence from alcohol and other drugs prior to and during pregnancy.
- Reducing Barriers to Access - Federal, State, and local agencies should reduce barriers to the use of family planning services and increase access to early prenatal care and other health services, including drug rehabilitation.
- Interdisciplinary Treatment - Interdisciplinary intervention for the mother and her offspring (and the father, when possible) should be available at all points of access to care. Professionals involved in this care should include obstetricians, neonatologists, pediatricians, nurses, nutritionists, mental health professionals, social workers, substance abuse counselors, and child development specialists, at a minimum.
- Staying Abreast of New Information - The medical literature is replete with research and anecdotal observations on the effects of drugs and alcohol on the infant. Long-term studies of exposure to opiates are sparse, and few systematic studies of long-term alcohol effects are available (Streissguth et al., 1991; Kaltenbach and Finnegan, 1992). Recent research has documented the possible long-term effect of maternal marijuana use on the infant (Fried, 1991).^ 1 ^ Longitudinal followup investigations on the effects of in utero cocaine exposure are in progress. Clinicians are encouraged to review the available literature, much of which is cited in the bibliography included in this TIP.
  1 The research documents aspects of neurobehavioral development in 36- and 48-month-old children. At 48 months, significantly lower scores in verbal and memory domains were associated with maternal marijuana use after adjusting for confounding variables. This negative relationship is the first reported association beyond the neonatal stage, and may represent a long-term effect of the drug upon complex behavior that, at a younger age, had not developed and/or could not be assessed.

Attempts to assess the effects of drug exposure on newborns are confounded by numerous medical and environmental variables. However, acknowledging these limitations, the TIP consensus panel offers these guidelines to the medical management of drug-exposed infants. In utero exposure to opiates (heroin and methadone) and cocaine is emphasized. Many of the suggested approaches are also applicable to infants exposed prenatally to other drugs, including alcohol. It is very important to remember that alcohol use frequently coexists with other forms of substance abuse. A brief discussion of alcohol-related effects on infants is included for information.

Readers should note that an earlier publication in this series, Pregnant, Substance-Using Women, provides extensive information on labor and delivery management and infection control for high-risk pregnancies. This panel endorses those recommendations.

## Alcohol Use in Pregnancy ^ 2 2 Information in this section is based on data from Pietrantoni and Knappel, 1991. ^

Abuse of alcohol is a significant societal problem in the United States; approximately 18 million Americans are chronic consumers of alcohol. Current estimates indicate that between 8 and 11 percent of women of childbearing age are either problem drinkers or alcoholics. Alcohol abuse exists within all socioeconomic levels of society. Review of drinking habits during pregnancy should form an essential part of perinatal history taking.

No safe level of alcohol consumption during pregnancy has been determined. Alcohol exposure in utero may result in a spectrum of abnormalities of fetal growth and development. Maternal consumption of 2 to 3 ounces of alcohol daily, often in association with "binge drinking," is frequently associated with fetal alcohol syndrome (FAS). Lesser intake of alcohol may produce subcombinations of signs of FAS; these lesser signs have been called fetal alcohol effects (FAE).

The effects of alcohol abuse during pregnancy can be summarized as follows:

1. Adverse Pregnancy Outcome, including an increased risk of spontaneous abortion.
2. FAS - The worldwide incidence of FAS is 1-3 births per 1,000 live births. To make the diagnosis of FAS, one abnormality from each of the following categories must be present:
  a. Prenatal or postnatal growth retardation; failure to thrive (weight, length, and / or head circumference less than the 10th percentile).
  b. Central nervous system dysfunction, including intellectual, neurologic, and behavioral deficits manifested as mild to moderate mental retardation, hypotonia (poor muscle tone), irritability in infancy, and later hyperactivity in childhood. Mental abnormality occurs in 85 percent of FAS children, and although IQ scores vary, affected children rarely show normal mental ability.
  c. Facial dysmorphology (structural abnormalities) including at least two of three characteristics:
    1. Microcephaly (head circumference less than the 10th percentile).
    2. Microphthalmia (abnormal smallness of the eye) or short palpebral fissures, ptosis (dropping eyelid), strabismus (imbalance of the eye muscles), or epicanthal folds (folds of the skin of the upper eyelid over the eye).
    3. Poorly developed philtrum, thin upper lip (vermilion border), short upturned nose, or flattening or absence of the maxilla (upper jaw).
3. FAE - Lesser degree of effect.

## Diagnosis of In Utero Drug Exposure

### Maternal Substance Use History

A maternal AOD use interview should be conducted at the earliest point of access into the health care system. (If possible, information about paternal substance use should also be obtained by interviewing the father or questioning the mother.) Despite concerted efforts by health care professionals to promote prenatal care, the mother may not have received such care and the delivery hospitalization may be the only opportunity to elicit information on the nature and extent of the infant's in utero exposure to drugs and alcohol. The mother's concern for her infant's health may encourage valid responses; conversely, fear of legal reprisals or loss of custody of the infant may cause the mother to deny drug use.

The AOD use interview should be conducted in as private a setting as possible and in a nonthreatening and nonjudgmental manner. Guidelines for the maternal substance use assessment, including psychosocial and mental health assessment, were developed by the consensus panel on Pregnant, Substance-Using Women and are repeated here with minor modifications.

1. The AOD use history taking should include legal and illegal drugs (prescription drugs, alcohol, and cigarettes), and should cover:
  - Duration of use, including age of first use
  - Frequency, type, and amount of drugs used and periods of abstinence
  - Route of administration
  - Social context of use (with whom the patient uses, where and when she uses)
  - AOD abuse treatment history
  - Support group involvement
  - Consequences of use (self-perceived and objective)
  - Relapse factors
  - Family history of use
  - Motivation for treatment
  - Motivation for continued use of drugs
  - Urine toxicologies as needed: A urine toxicology is indicated when an adequate drug history cannot be obtained from the mother and she is manifesting symptoms of possible addiction or withdrawal and when the child is showing signs or symptoms of withdrawal.
2. A psychosocial assessment should include:
  - Support systems (role of the patient in her family support system and the stress created by that system)
  - Patient's attitude toward the birth of this child and her perception of her ability to parent this child and any older children
  - Role of the father, both in the mother's life and his potential role with the child
  - Education and employment
  - History of physical, sexual, and emotional abuse, both as a child and as an adult
  - Current life situation, including housing, transportation, child care, monetary support, and legal considerations or problems.
3. The mental health assessment should cover:
  - Mental status examination
  - Psychiatric symptomatology
  - Psychiatric history and treatment
  - Suicide risk
  - Family psychiatric history
  - DSM-III-R diagnosis
  - Treatment recommendations.

Standardized psychiatric evaluation tools can be helpful in diagnosis and followup. Further, liaison and ongoing contact must be maintained with other members of the assessment and treatment team.

### Treatment Planning

Treatment planning for mothers and involvement of representatives from all participating agencies should include referral to an appropriate AOD abuse treatment program and continued involvement with medical and psychosocial agencies. Adequate arrangements should be made to ensure that the mother can get to the treatment facility, which may, in certain instances, require the provision of transportation for the mother to the location. An indepth treatment plan should be developed for the infant through multidisciplinary efforts of doctors, nurses, social workers, and others. The mother and father should be given the opportunity and urged to take part in treatment planning. If assessment reveals that the infant may be at risk for future harm due to the mother's potential for abuse or neglect, a report should be made to the child protective services agency so that further evaluation can occur. Chapter 4 sets forth guidelines for referrals to child protective services. At a minimum, the treatment team must develop a clear followup plan for the infant upon discharge from the hospital, and must arrange for careful monitoring of compliance with the plan. Guidelines for followup are detailed in Chapter 3.

### Toxicology Screening of Mothers and Infants

As stated above, maternal AOD use history should be complemented by toxicology screening of the mother and / or infant at the time of delivery only in certain situations (when a complete drug history cannot be obtained and the mother is manifesting symptoms of possible addiction and withdrawal and when the infant is showing withdrawal signs.) Guidelines on urine toxicology from the TIP, Pregnant, Substance-Using Women, appear in Appendix C.

### Legal and Ethical Considerations

The diagnosis of infants with in utero drug exposure has significant legal and ethical ramifications. These are discussed in Chapter 5.

## Medical Assessment of the Drug-Exposed Neonate

### Physical Examination

A thorough physical examination of the neonate should include accurate assessment of weight, length, and head circumference and a standardized assessment of gestational age. Special attention should be paid to signs of intrauterine growth retardation, microcephaly or decreased head circumference, prematurity, congenital infection, and major and minor congenital malformations. Various tools and scoring systems can be used to chart and compare the infant's neuromuscular and physical maturity and size to normal ranges for infants (Ballard et al., 1977; Ballard et al., 1979; Brazelton, 1984; Lubchenco et al., 1966). The Newborn Maturity Rating and Classification chart is reproduced in Exhibit 1.

Exhibit 1: Newborn Maturity Rating and Classification & Classification of Newborns Based on Maturity and Intrauterine Growth

Exhibit 1 of TIP 5: Improving Treatment for Drug-Exposed Infants is not available electronically. A copy of the entire TIP containing Exhibit 1 can be ordered from the National Clearinghouse of Drug and Alcohol Information (NCADI). The order number for TIP 5: Improving Treatment for Drug-Exposed Infants is BKD110. It is free and can be ordered from NCADI's electronic catalog at http://www.health.org/pubs/catalog/ordering.htm" (http://www.health.org/pubs/catalog/ordering.htm) or by calling 1-800-729-6686.

### Screening for Congenital Infection

Drug-exposed infants are at increased risk of acquiring infections transmitted from mothers whose lifestyles include unsafe sexual practices or intravenous drug abuse. Assessment of the mother for sexually transmitted diseases and human immunodeficiency virus (HIV) should be incorporated into the prenatal care setting and delivery hospitalization.

1. Quality improvement guidelines should be established within each institution to assess periodically the prevalence of HIV infection among pregnant women anonymously screened on a random or consecutive sample population.
2. AOD-using pregnant women should receive routine screening for syphilis, hepatitis B, gonorrhea, and chlamydia.
3. AOD-using pregnant women should be offered confidential or anonymous screening for the HIV-1 virus with appropriate pre- and post-test counseling.
4. Quality improvement guidelines should be established within each institution to review the incidence of sexually transmitted diseases among pregnant women and their impact upon the infants and the health care delivery system.
5. Quality improvement guidelines should be established within each institution to ensure utilization of updated recommendations for medical management of neonates exposed to HIV, hepatitis B, syphilis, gonorrhea, and chlamydia (Prober and Gershon, 1991).
6. Quality improvement guidelines should include universal precautions for infection control in the delivery service and neonatal nurseries.

## In Utero Exposure To Opiates: Effects And Treatment

### Effects of In Utero Heroin Exposure

The effects of heroin on the neonate are as follows:

1. Low Birth Weight - The low birth weight is due primarily to symmetric intrauterine growth retardation. Low birth weight may also be due to prematurity. In either case, low birth weight results in the slowing of both body and head growth. (See definitions of medical terms in Appendix F.)
2. Meconium Aspiration - Meconium aspiration may be caused by hypoxia in association with antepartum or intrapartum passage of meconium secondary to fetal stress.
3. Neonatal Abstinence Syndrome (Withdrawal) - Neonatal abstinence syndrome occurs in about 60 to 80 percent of heroin-exposed infants. Its onset is usually within 72 hours of birth, with possible mortality if the syndrome is severe and untreated. The syndrome involves several body systems. Central nervous system (CNS) signs of abstinence include irritability, hypertonia, hyperreflexia, abnormal suck, and poor feeding. Skin abrasions may result from general hyperactivity. Seizures are seen in 1 to 3 percent of heroin-exposed infants. Gastrointestinal signs include diarrhea and vomiting. Respiratory signs include tachypnea, hyperpnea, and respiratory alkalosis. Autonomic signs include sneezing, yawning, lacrimation, sweating, and hyperpyrexia. If the infant is hypermetabolic, the postnatal weight loss may be excessive and subsequent weight gain suboptimal unless higher caloric intake is provided. In cases demonstrating signs suggestive of the abstinence syndrome, other diagnoses should also receive the clinician's full attention. For example, sepsis, metabolic disorders, and CNS hemorrhage or ischemia should be considered in making the differential diagnosis. Premature infants seem to manifest fewer overt symptoms of opiate abstinence syndrome. These differences may be due to the developmental immaturity of the preterm CNS, which might ameliorate the clinical appearance of abstinence symptoms, or to variations in total drug exposure due to a shortened gestation (Doberczak, Kandall, and Willets, 1991).
4. Delayed Effects - Delayed effects include subacute withdrawal with symptoms such as restlessness, agitation, irritability, and poor socialization that may persist for 4 to 6 months.
5. Sudden Infant Death Syndrome (SIDS) - Epidemiologic studies suggest an association between SIDS and interuterine exposure to opiates (including methadone), but somewhat weaker links between SIDS and cocaine exposure (Kandall and Gaines, 1991).
6. Effects of mother's behavior - Adverse effects may be due to the life circumstances and behavior of the mother who uses heroin. Lack of prenatal care, poor nutrition, medical problems and the abuse of other drugs pose significant risk to the mother and the fetus. In addition, heroin use can cause sexual disinhibition, which increases the possibility of the mother's engaging in behaviors that place her at high risk for contracting HIV, such as sharing needles. Or the addicted mother may engage in sex for drugs with partners infected with HIV and other sexually transmitted diseases (STDs).

### Effects of In Utero Methadone Exposure

Maternal methadone maintenance is a valuable treatment modality when administered under medical supervision. Although methadone poses some threat to the fetus, it is important to contrast the benefits of methadone in pregnancy with the risks associated with the continuing use of heroin. For this reason, methadone maintenance is often recommended for pregnant opioid-dependent women.

### Benefits of Methadone Maintenance During Pregnancy

1. Assists women in staying heroin free - The purpose of methadone is to provide an opioid-dependent individual with a legal alternative to an illicit substance, the effects of which can be monitored by a medical professional as the individual goes through withdrawal and after withdrawal. Methadone maintenance reinforces the woman's desire to abstain from using heroin. Off heroin, the woman is in a better position to manage her life so as to maximize the possibilities for a healthy lifestyle for herself and her baby.
2. Leads to more consistent prenatal care - Studies have shown that methadone maintenance leads to more consistent prenatal care, giving medical providers and others involved the opportunity to better manage the pregnancy and the various aspects of the pregnant woman's care.
3. Lessens possibility of fetal death - Maternal opiate withdrawal can cause fetal death (Hoegerman and Schnoll, 1991). Significant opiate use is associated with increased pregnancy loss. The incidence of pregnancy loss is definitely decreased if the woman is maintained on methadone.
4. Lessens decreased fetal growth and improves growth of newborn - Significant opiate use is associated with decreased fetal growth and affects the growth of the newborn. Once the baby is born, the baby will often develop more normally if the mother has been maintained on methadone.
5. Reduces risk of HIV infection - Methadone maintenance reduces the transmission of HIV (Blix et al., 1988; Cooper, 1989). Women maintained on methadone do not spread the growth of the HIV virus as do women who use morphine, cocaine, and heroin (ADAMHA News [2], 1992). The reason for the reduced HIV rate is that the use of methadone decreases the practice of high-risk behaviors (unsafe sex and the sharing of used intravenous needles that may contain HIV-infected blood products).
6. Enables the woman to breastfeed her infant - Breastfeeding is not contraindicated if the woman is methadone maintained. Thus, if they are HIV-negative and free of other drug use, women on methadone can be encouraged to breastfeed their babies. Given the well-established importance of breastfeeding in the mother-infant bonding process, the fact that methadone-maintained women can often breastfeed their infants is of vital significance. This advantage to methadone should be emphasized by providers when assisting women in the decisionmaking process regarding whether to begin methadone maintenance.

### Risks of In Utero Methadone Exposure

Despite the significant advantages of methadone to an opioid-dependent pregnant woman, dangers to the fetus and to the newborn still exist, as described below.

1. Low Birth Weight - In utero exposure to methadone may lead to low birth weight caused by symmetric fetal growth retardation involving fetal weight, length, and head circumference. There is a lack of consensus on the appropriate methadone dosage schedule during pregnancy. Some studies indicate that a higher dose in the first trimester leads to a more optimal birth weight. Thus, a higher dosing schedule during this period may be considered (Kandall et al., 1976).
2. Neonatal Methadone Abstinence Syndrome - Although the neonatal methadone abstinence syndrome is similar to that of heroin, it is typically more severe. Whether severity is related to maternal dosage is controversial (Harper et al., 1977). Late withdrawal can occur at 2 to 3 weeks of age, and subacute withdrawal can persist until 6 months of age. These phenomena may be related to variations in the metabolism of methadone due to placental transfer or neonatal metabolism. Methadone is also known to accumulate in CNS tissue (Finnegan and Kaltenbach, 1992.)
3. Seizures - Seizures attributed to withdrawal will be seen in some drug-exposed infants. For example, in one study of 301 neonates passively addicted to narcotics, 18 had seizures attributed to withdrawal (Herzlinger et al., 1977). Some studies have shown that infants exposed to methadone may have an increased incidence of seizures (Herzlinger et al., 1977; Harper et al., 1974). Others in the field believe that it is actually the use of diazepam and phenobarbital that increases the incidence of seizures in methadone-exposed babies. The latter recommend the use of paregoric.
4. Thrombocytosis - At 4 to 10 weeks, methadone-exposed neonates are at risk to develop thrombocytosis, which may persist for 6 to 10 months (Burstein et al., 1979).
5. Hyperthyroid State - Elevation of T3 and T4 during the first week of life has been documented (Jhaveri et al., 1980).
6. SIDS - When controlled for other high-risk variables, the rate of SIDS among opiate-exposed infants is about 3-4 times higher than in the general population. The increased rate of SIDS is less impressive for cocaine-exposed infants (Kandall and Gaines, 1991; Kandall et al., 1993).

### Treatment Protocol for Opiate-Exposed Infants

1. Neonates exposed in utero to opiates should be examined systematically for signs of neonatal abstinence syndrome to assess the need for intervention. A standardized assessment tool (Finnegan et al., 1975) appears as Exhibit 2 . The protocol for opiate-exposed infants is summarized in Exhibit 3 , and is discussed in detail below.
2. Paregoric has been found to decrease seizure activity, increase sucking coordination, and decrease the incidence of explosive stools. Phenobarbital is also a commonly used agent, and may be especially helpful in cases of polydrug abuse. Other specific agents have been considered in the treatment of neonatal abstinence syndrome, but experience with morphine, methadone, chlorpromazine, and rauwolfia is much too limited to support their use. Diazepam has been used to treat neonatal abstinence, but this agent controls seizures poorly and may lead to respiratory depression in the neonate (Finnegan and Ehrlich, 1990).
3. Naloxone is sometimes given to newborns to reverse the perinatally acquired effects of analgesics administered to the mother during labor and delivery. Naloxone is contraindicated in opiate-exposed infants with respiratory depression due to its potential for precipitating a severe narcotic withdrawal. Naloxone is not specifically contraindicated for infants born to cocaine-using mothers, but providers should be aware that such mothers may be polydrug abusers who have also used opiates and that in this circumstance, naloxone may precipitate narcotic withdrawal in the infant.
4. Modification of the infant's environment - by placing the infant in a dimly-lit, quiet room; swaddling him or her; and using a nonoscillating waterbed if available - may be useful. However, this environmental modification does not eliminate the need for close observation of the infant. Drug-exposed infants in a prone or lateral position are generally comforted best. But caretakers should note an ongoing debate over prone versus supine positioning as possible factors in SIDS.

Exhibit 2: Neonatal Abstinence Score

Exhibit 2 Neonatal Abstinence Score
SYSTEM | SIGNS AND SYMPTOMS | SCORE | AM | | | | | | PM | | | | | | COMMENTS
CENTRAL NERVOUS SYSTEM DISTURBANCES | Excessive High Pitched (other) Cry Continuous High Pitched (other) Cry | 2 3
CENTRAL NERVOUS SYSTEM DISTURBANCES | Sleeps < 1 hour after feeding Sleeps < 2 hours after feeding Sleeps < 3 hours after feeding | 3 2 1
CENTRAL NERVOUS SYSTEM DISTURBANCES | Hyperactive Moro reflex Markedly Hyperactive Moro reflex | 2 3
CENTRAL NERVOUS SYSTEM DISTURBANCES | Mild Tremors Undisturbed Moderate- Severe Tremors Undisturbed | 3 4
CENTRAL NERVOUS SYSTEM DISTURBANCES | Increased Muscle Tone | 2
CENTRAL NERVOUS SYSTEM DISTURBANCES | Excoriation (specific areas) | 1
CENTRAL NERVOUS SYSTEM DISTURBANCES | Myocionic Jerks | 3
CENTRAL NERVOUS SYSTEM DISTURBANCES | Generalized Convulsions | 5
METABOLIC/ VASCOMOTOR/ RESPIRATORY DISTURBANCES | Sweating | 1
METABOLIC/ VASCOMOTOR/ RESPIRATORY DISTURBANCES | Fever < 101 (99-100.8F/37.2-38.2C) Fevers > 101 (38.4C and higher) | 1 2
METABOLIC/ VASCOMOTOR/ RESPIRATORY DISTURBANCES | Frequent Yawning (>3-4 times/interval) | 1
METABOLIC/ VASCOMOTOR/ RESPIRATORY DISTURBANCES | Mottling | 1
METABOLIC/ VASCOMOTOR/ RESPIRATORY DISTURBANCES | Nasal Stuffiness | 1
METABOLIC/ VASCOMOTOR/ RESPIRATORY DISTURBANCES | Sneezing (>304 times/interval) | 1
METABOLIC/ VASCOMOTOR/ RESPIRATORY DISTURBANCES | Nasal Flaring | 2
METABOLIC/ VASCOMOTOR/ RESPIRATORY DISTURBANCES | Respiratory Rate > 60/min. Respiratory Rate > 60/min with retractions | 1 2
GASTRO- INTESTINAL DISTURBANCES | Excessive Sucking | 1
GASTRO- INTESTINAL DISTURBANCES | Poor Feeding | 2
GASTRO- INTESTINAL DISTURBANCES | Regurgitation Projectile Vomiting | 2 3
GASTRO- INTESTINAL DISTURBANCES | Loose Stools Water Stools | 2 2
TOTAL SCORE
INITIALS OF SCORER
Evaluator should place a check next to each sign or symptom observed at various time intervals, then add scores for total score.

* Finnegan, L.P and K. Kaltenbach, 1992. Neonatal Abstinence Syndrome. in Primary Pediatric Care, Edition 2, Hoekelman and Nelson (Eds.), Mosby Yearbook, Inc., St. Louis, MO., pp. 1367-1378.Aiken, Faren R., Aikens, Diannal., and Mace, Gillian. 1981. Parent-child separation: psychosocial effects on development: an abstracted bibliography. New York: IFI/Plenum.

Bigner, Jerry J. 1979. Parent-child relations: an introduction to parenting. New York: MacMillan.

DeRosis, Helen. 1974. Parent power/child power: a new tested method for parenting without guilt. Indianapolis: Bob-Merrill.

Levy, Stephen Jay and Rutter, Eileen. 1991. Children of drug abusers. New York: Lexington Books.

Sinanogulu, Paul A. and Malcuccio, Anthony N. 1981. Parents of children in placement: perspectives and programs. New York: University of Connecticut School of Social Work/Child Welfare League of America.

Exhibit 3: Pharmacologic Treatment of Opiate Withdrawal

Exhibit 3 Pharmacologic Treatment of Opiate Withdrawal
Drug | Dose | Considerations
Paregoric (0.4mg MS/cc) | 0.2mL every 3 hrs. (PO) up to max of 0.4mL every 3 hrs. Gradually decrease dose every other day by 0.05mL/dose as tolerated. After stabilization for 5 days, taper the dose cautiously. | If abstinence syndrome remains uncontrolled, add phenobarbital. Observation of infant should be maintained for 1-2 days after discontinuing drugs.
Phenobarbital | Loading dose: 5 mg/kg IM, IV Maintenance dose: 3-5mg/kg/day (PO, IM, or IV) divided into doses every 8 hrs. Increase as needed, by 1mg/kg to maximum of 10mg/kg for 5 days, then reduce by 1mg/kg every other day or as clinically indicated. | After stabilization for 5 days, taper the dose cautiously. Serum phenobarbital should be monitored when clinically indicated. Excessive phenobarbital dose may cause poor feeding behavior and lethargy.

### Interventions for Opiate-Related Withdrawal Seizures

Exhibit 4 presents pharmacologic interventions for seizures associated with opiate withdrawal. Diagnostic evaluation of seizures associated with opiate withdrawal should include:

1. Full sepsis workup.
2. Metabolic workup including tests of blood sugar, electrolytes, calcium, phosphorus, and mag-nesium levels and arterial blood gases.
3. Central nervous system imaging (cranial ultrasound, coaxial tomography [CT], or magnetic resonance imaging [MRI]).
4. An electroencephalogram (EEG). If the EEG is normal, levels of phenobarbital (Bellegral-S®, Donnatal®) and then paregoric should be tapered. Fifty percent of opiate-exposed infants will have an abnormal first EEG. If the EEG remains abnormal, a pediatric neurologist should be consulted for possible maintenance anticonvulsant treatment.

Exhibit 4: Pharmacologic Intervention for Neonatal Abstinence Seizures

Exhibit 4 Pharmacologic Intervention for Neonatal Abstinence Seizures
Drug | Dose | Comments
Phenobarbital | Loading dose: 10mg IV push; repeat with another 10mg/kg in 10 minutes. Maintenance: 24 hrs after loading dose, start 3-5 mg/kg divided in q12 h doses | Maintain therapeutic range by following levels.
Dilantin | Loading dose: 10mg/kg IV; repeat with another 10mg/kg in 20 minutes Maintenance: 12 hrs after loading dose, start 5-7mg/kg/d divided in doses every 12 hr. | Maintain therapeutic range by following levels.
NOTE: If patient is not on paregoric, paregoric treatment regimen should be implemented.

## In Utero Exposure To Cocaine: Effects And Treatment

### Effects of Cocaine Exposure on the Neonate

The abuse of cocaine became an alarming problem during the last decade. It is estimated that up to 8 million Americans use cocaine regularly and 30 to 40 percent of cocaine addicts are women. Cocaine use by pregnant women has multiple adverse influences on the mother's health, pregnancy outcome, and the well-being of the infants as discussed in recent review articles (Bandstra and Burkett, 1991; Dixon and Bejar, 1989; Dixon, Bresnahan, and Zuckerman, 1990; and Kandall, 1991, a and b). These effects are summarized in Exhibit 5 , and are discussed in detail below.

Exhibit 5: Possible Complications of Maternal and Neonatal Effects of Cocaine Use That May Occur in Pregnancy

Exhibit 5 Possible Complications of Maternal and Neonatal Effects of Cocaine Use That May Occur in Pregnancy
Maternal Complications:; - Poor nutritional status; - Increased risk for infections; - Hypertension/tachycardia/arrhythmias/myocardial infarctions; - Central nervous system hemorrhage; - Depression and low self-esteem; - Increased tendency to engage in risk behaviors for HIV
Pregnancy, Labor, and Delivery Complications:; - Spontaneous abortion; - Poor weight gain; - Abruptio placentae; - Fetal demise; - Precipitous delivery
Neonatal Complications:; - Intrauterine growth retardation; - Microcephaly or reduced head circumference; - Prematurity; - Congenital malformations/vascular disruption; - Congenital infections; - Cardiovascular dysfunction/arrhythmias; - Feeding difficulties/necrotizing enterocolitis; - Central nervous system hemorrhagic-ischemic lesions; - Neurobehavioral dysfunction; - Seizure activity; - Sudden infant death syndrome (SIDS); - Increased possibility of HIV involvement

As with heroin addiction, adverse effects may be due to the life circumstances and behavior of the mother as well as to the pharmacologic properties of cocaine itself.

Lack of prenatal care, poor nutrition, medical problems, and abuse of other drugs and alcohol pose significant risk to the mother and the fetus. In addition, cocaine use increases the possibility of the mother's engaging in behaviors such as unprotected sex that place her at risk for contracting HIV.

The pharmacologic action of cocaine inhibits uptake of norepinephrine in the synaptic cleft, thus leading to vasoconstriction, hypertension, and tachycardia. In animal models, cocaine increases uterine vascular resistance and decreases uterine blood flow with resulting fetal hypoxemia.

Therefore, cocaine may play an etiologic role in causation of abruptio placentae, premature labor, intrauterine growth retardation, and fetal vascular disruption. Cocaine exposure causes a direct neurotoxicity manifested by neurobehavioral disturbances that are usually less striking than those associated with opiate abstinence syndrome.

These neurobehavioral disturbances may be transient, and usually do not require treatment. An encephalopathic syndrome - including irritability, tremulousness, lethargy, somnolence, labile state, decreased habituation, and visual tracking difficulties - has been described in cocaine-exposed newborn infants by many investigators. In addition to clinical signs of cocaine-induced neurotoxicity, transient encephalographic abnormalities can be demonstrated in this population of infants. Besides clinical and encephalographic abnormalities, echoencephalographic abnormalities are found in some cocaine-exposed infants (Dixon and Bejar, 1989). Lesions varying from ischemic injury with cavitation to intraventricular hemorrhage and ventricular dilation are observed in 8-14 percent of the study population. Cerebral infarctions have also been described in other reports. In some infants, physiologic dysfunction is indicated by alterations in vital signs including tachycardia and hypertension, and cardiac arrhythmias. The risk of sudden infant death syndrome in this population of infants may be increased, but large epidemiologic studies are needed in order to differentiate between effects of cocaine and other factors, such as low socioeconomic status, polydrug abuse, and smoking.

Long-term effects of intrauterine cocaine exposure, as well as poly-drug exposure, are described in anecdotal reports, and include attention deficits, flat apathetic moods, decreased fantasy play, and other observations. However, long-term followup studies of cocaine-exposed children are scarce at present (Chasnoff et al., 1992).

Subtle neurobehavioral aberrations may persist beyond the neonatal period. Cocaine may produce long-term neurodysfunction, which is now being described anecdotally among the first cohort of babies exposed to crack in utero as they enter nursery school. The biologic vulnerability of infants exposed to crack in utero is modulated by the environment. The poor psychosocial, nutritional, medical, and socioeconomic status of the mother can all contribute to long-term neurodysfunctional sequelae in the infant (Mayes et al., 1992; Zuckerman and Frank, 1992). Additional risk factors - including intrauterine growth retardation, CNS pathology, prolonged hospitalization, and lack of intellectual nurturing - must be taken into consideration in evaluation of long-term neurobehavioral outcome of cocaine-exposed infants.

### Treatment for Cocaine-Exposed Neonates

Treatment for the neonate demands an appropriate nursery environment, comprehensive assessments, pharmacologic intervention, and clinical diagnostic studies.

1. Optimal Nursery Environment - Such an environment features sound primary nursing care, gentle handling by as few caretakers as possible, and an avoidance of stimuli such as light and noise that will irritate the baby. To facilitate and promote optimal infant growth and development, nursery personnel should carefully monitor feeds, initiate strategies to facilitate intake for those infants experiencing feeding difficulties, observe for feeding intolerance or necrotizing enterocolitis, provide opportunities to interact with parents and environment as the infant is able to tolerate them, and provide primary nursing to facilitate parent-infant interactions.
2. Brazelton Neonatal Behavioral Assessment Scale - Use of the Brazelton Neonatal Behavioral Assessment Scale (Brazelton, 1984) is encouraged. This scale has been used extensively to evaluate newborn behavior such as habituation and responsivity to stimuli (faces, voices, light, bell, rattle, etc.); state (sleeping, alertness); characteristics of changes in state (irritability, inconsolability); and neurological and motor development. Although clinical expertise is demanded to administer the Brazelton Scale, programs will find it useful in evaluating infants exposed to drugs (Finnegan, 1986).
3. Neonatal Neurotoxicity Assessment - While asymptomatic infants do not need to be systematically assessed for neonatal neurotoxicity, consideration should be given to developing scoring criteria for those infants who are symptomatic. In the presence of significant withdrawal symptoms, other etiologies, including polydrug and alcohol exposure and metabolic problems, should be explored.
4. Pharmacotherapy - If irritability persists in an infant, a short course of phenobarbital is recommended.
5. Central Nervous System Imaging - Cranial sonograms are not routinely recommended, but recent literature is suggestive of CNS abnormalities, including hemorrhagic ischemic lesions in some drug-exposed infants. (Dixon and Bejar, 1989; Heier et al., 1991 a and b). As yet, evidence is insufficient to support a mandate for cranial sonograms in all cocaine-exposed infants. However, special consideration should be given to specific neuroimaging of cocaine-exposed preterm infants, infants whose head circumference falls below the 10th percentile on standardized fetal growth curves, and infants with abnormal neurologic signs, neurobehavioral dysfunction, or seizure activity.
6. Assessment for Congenital Malformations / Vascular Disruptions - Clinicians should have a heightened awareness of the possibility of uncommon but significant congenital malformations or vascular disruptions reported in cocaine-exposed neonates. Systems that may be affected include the genitourinary tract, cardiovascular system (congenital heart malformations), gastrointestinal tract, and skeletal system. Echocardiography and abdominal ultrasound are not currently recommended as routine assessments in cocaine-exposed infants, but should be performed based on clinical indications.
7. Sudden Infant Death Syndrome - As indicated earlier, SIDS is a multifactorial problem, and opiate exposure is known to increase the neonate's risk of SIDS. There is some controversy over the incidence of SIDS in cocaine-exposed infants, but crack cocaine does appear to raise the risk slightly over controls. Data also suggest that cocaine-exposed infants may exhibit respiratory dysfunction. There are no indications that apnea monitoring decreases the incidence of SIDS. Routine home apnea monitoring for drug-exposed infants is therefore not recommended.

## Promoting Positive Mother-Infant Interaction

Hospitals can promote positive interaction between parents and infants by adopting liberal visiting policies and mother-infant interaction time for newborn nurseries. Two other areas of concern are breastfeeding and instruction of mothers in handling drug-exposed infants.

### Breastfeeding Drug-Exposed Infants

Breastfeeding is a key area of concern, especially among substance-using women. The advantages of breastfeeding are many, and are well documented. Benefits include the fact that breastfeeding strengthens the bond between the mother and the infant - an advantage that is of vital importance. Despite the instances described below, when breastfeeding is contraindicated, the decision on the part of service providers to advise women against breastfeeding should not be made without careful thought and training, taking into account the particular circumstances of the individual woman. Service providers must often become active breastfeeding advocates, encouraging the mother to breastfeed despite initial resistance to do so and educating her on breastfeeding's advantages to both herself and the newborn.

Nonetheless, there are instances when breastfeeding of drug-exposed infants is contraindicated. Since most drugs are secreted in breast milk, it has often been the practice to advise drug-using mothers not to breastfeed. Women who have been actively using drugs through the pregnancy and after the delivery have been discouraged from breastfeeding because of a number of factors including possible drug toxicity from diverse agents in varying levels, including the risk of exposure to drugs used intravenously, and the mother's medical and nutritional problems associated with continued drug use. Cocaine readily passes into breast milk and may lead to neonatal neurotoxicity, including irritability, tremors, brisk reflexes, mood lability, and even seizures. In addition, breastfeeding is contraindicated if the mother is HIV positive. (It should be noted, however, that the HIV status of the mother may not be known to the care provider or the mother.)

Despite these warnings, the well-known advantages of breastfeeding have led to a reconsideration of breastfeeding in selected substance-using women. There are two kinds of situations, highlighted below, in which care providers might wish to recommend that substance-using women breastfeed their babies: when the woman is on methadone or abstinent.

- In many instances, women who are methadone-maintained should be encouraged to breastfeed, particularly if the woman is known to be HIV-negative and free of other drug use. The fact that breastfeeding is not contraindicated among methadone-maintained patients is an advantage to methadone that is sometimes underemphasized, yet is of crucial importance.
- The recovering user of other substances (including cocaine), who has complied with rehabilitation and been documented to be AOD-free for a suitable period of time before delivery, may be able to breastfeed the infant, provided she continues to abstain from AODs and consents to frequent, random toxicology screens.

In sum, the recommendation regarding whether a substance-using woman should breastfeed her newborn should be made on an individual basis, taking a variety of factors into account. Service providers should receive ongoing training on the issue to keep up with the latest developments in the field.

### Instructions in Infant Handling

Parents and other providers of primary care should be taught (Gardner et al., 1989):

- To assess the baby, interpret his or her cues for more or less interaction, and synchronize one's behavior with that of the infant.
- To organize care and handling so that the baby is not bombarded by multiple stimuli that overwhelm her or his limited ability to habituate.
- To utilize graduated interventions in quieting the fussy, irritable baby.
- To appreciate the infant's unique competencies: The baby's ability to see, hear, and interact with the environment.

## Discharging the Drug-Exposed Infant from the Hospital

It is often quite difficult to follow an AOD-using mother and her newborn after release from the hospital, and thus it is vital that the infant and the mother not be discharged too early. According to the Newborn Assessment Score, most babies (96 percent) are symptom-free of withdrawal seizures by the third or fourth day after birth and might otherwise be ready to be discharged from the hospital. However, a small but significant percentage of babies present with withdrawal seizures within 7 to 10 days after birth. For this reason, it is important to closely monitor the drug-exposed infant to determine if he or she needs to remain in the hospital after 4 days. Other medical, social, or environmental issues may further prolong the need for hospitalization (Doberczak et al., 1988).

### Discharge Criteria

The infant's discharge should occur after the following criteria are met:

1. The infant is taking oral feeds and gaining weight satisfactorily.
2. The infant is physiologically stable (has normal vital signs including blood pressure).
3. The infant is showing neurobehavioral recovery (can reach full alert state, responds to social stimuli, and can be consoled with appropriate measures).
4. All necessary assessments have been completed, since adherence to followup schedules cannot be ensured.

### Discharge Instructions

1. The parent(s) or alternate primary care provider should receive anticipatory guidance (oral and written) regarding late and subacute withdrawal, seizures, behavioral interventions, and medications (side effects, route of administration, dose, etc.).
2. A home evaluation should be performed on all drug-exposed infants or those with multiple risks by a public health nurse or a protective social service worker within 7 days of discharge, when feasible.
3. A follow-up appointment for pediatric care should be scheduled within 2 to 4 weeks.
4. Mothers and fathers who are not already enrolled in drug abuse treatment and need to be should be referred to an accessible and suitable treatment program prior to the infant's discharge.
5. Facilitation of mother's postpartum gynecologic care and family planning should be incorporated into discharge planning of the infant.
6. To promote quality improvement, discharge planning instructions should be documented in medical records, and a discharge summary of the hospital course should be given to parents or alternate primary caregiver.

The following chapter gives further guidance on proper monitoring and care of the drug-exposed infant following discharge from the hospital.

Drug abuse during pregnancy is associated with medical, psychological, and economic problems that require extensive evaluation by qualified service providers. Mothers and fathers of drug-exposed infants need substance abuse treatment and a wide array of services to support them in their parenting role. Provision must be made for such services prior to an infant's discharge. Chapter 4 contains recommendations regarding psychosocial services for families of drug-exposed infants.