# Appendix I - Field Reviewers

- Antonia Abbey, Ph.D.
- Associate Professor of Community Medicine
- Department of Community Medicine
- Wayne State University
- Detroit, Michigan

- Barbara Bennett, M.D.
- Associate Clinical Professor of Pediatrics
- University of California
- San Francisco, California

- Diane Bingham, R.N.
- Local Program Director
- Prenatal Substance Use Prevention Program
- Union Hospital
- Terre Haute, Indiana

- Haywood L. Brown, M.D.
- Director, Wishard Community Health Center
- Wishard Memorial Hospital
- Indianapolis, Indiana

- Rebecca Burkart, M.M.Sc., CAC-II
- Director, Fulton County Substance Abuse Services
- Fulton County Alcohol and Drug Treatment Center
- Atlanta, Georgia

- Ronald H. Carlson
- Associate Administrator
- Health Resources and Services Administration
- Rockville, Maryland

- David F. Carpenter, Ph.D.
- State Laboratory Director
- Office of Health Protection
- Division of Laboratories
- Illinois Department of Public Health
- Springfield, Illinois

- Shirley D. Coletti
- President, Operation PAR, Inc.
- St. Petersburg, Florida

- Margaret Cone, M.Ed.
- Director for Adolescent and Women's Services
- Division of Mental Health, Mental Retardation and Substance Abuse
- Georgia Department of Human Resources
- Atlanta, Georgia

- Dorynne Czechowicz, M.D.
- Associate Director for Medical Professional Affairs
- National Institute on Drug Abuse
- Rockville, Maryland

- Norma Finkelstein, Ph.D., M.S.W.
- Director
- Coalition on Addiction, Pregnancy and Parenting
- Cambridge, Massachusetts

- Anthea Fox, M.S.
- Project Director
- Prenatal Substance Use Prevention Program
- Tri-Cap E.O.C., Inc.
- Jasper, Indiana

- Catherine Gorham, C.S.W.
- Project Development Specialist
- Texas Commission on Alcohol and Drug Abuse
- Austin, Texas

- Gloria J. Hamilton, Ph.D.
- Assistant Professor
- Clinical Psychologist
- Middle Tennessee State University
- Murfreesboro, Tennessee

- Virginia H. Jones, M.D.
- Associate Clinical Professor of Pediatrics
- Ohio State University
- Columbus, Ohio

- Lorraine V. Klerman, Ph.D.
- Professor and Director
- Maternal and Child Health Program
- School of Public Health
- University of Alabama at Birmingham
- Birmingham, Alabama

- Kay Malone, R.N., C.D., M.H.S.
- Nursing Supervisor/Project Director
- Brandywine Counseling Inc.
- Wilmington, Delaware

- Lora-Ellen McKinney, Ph.D.
- Director
- Clearinghouse for Drug Exposed Children
- Division of Behavioral and Developmental Pediatrics
- University of California
- San Francisco, California

- Joseph Y. Morrison, Jr., M.D.
- Vice Chairman - Board
- Georgia Board of Human Resources
- Savannah, Georgia

- Charlotte Maxwell Newhart
- Chief Administrative Officer
- The American College of Obstetricians and Gynecologists
- District IX
- San Francisco, California

- Patricia A. Paluzzi, C.N.M., M.P.H
- Lead Nurse Midwife
- Center for Addiction & Pregnancy
- Frances Scott Key Medical Center
- Baltimore, Maryland

- Estella Parrott, M.D., M.P.H.
- Medical Officer
- Bureau of Primary Health Care
- Division of Primary Care Services
- Rockville, Maryland

- Jay Paulsen, M.D., M.P.H.
- Associate RHA for Clinical Affairs
- Region X
- U.S. Public Health Service
- Seattle, Washington

- J. Thomas Payte, M.D.
- Medical Director
- Drug Dependence Associates
- San Antonio, Texas

- Nancy A. Pyle, R.N., M.S.N., C.P.N.P.
- Prenatal Substance Abuse Prevention Program
- Three Rivers Health Services, Inc.
- Fort Wayne, Indiana

- Lois A. Schipper, R.N., M.P.H.
- Nurse Consultant
- Maternal and Child Health Bureau
- Rockville, Maryland

- Eugene P. Schoener, Ph.D.
- Director
- Addiction Research Institute
- Wayne State University School of Medicine
- Detroit, Michigan

- Manuel Schydlower, M.D.
- Director, Adolescent Medicine
- William Beaumont Army Medical Center
- El Paso, Texas

- Iris E. Smith, M.P.H.
- Director, Applied Research
- Human Behavior Genetics Laboratory
- Emory University School of Medicine
- Atlanta, Georgia

- Kenneth D. Stark, Director
- Department of Social and Health Services
- Division of Alcohol and Substance Abuse
- Olympia, Washington

- Carolyn Suchecki
- Quality Assurance Coordinator
- CT Alcohol & Drug Abuse Commission
- Hartford, Connecticut

- P. Imani Thompson, M.C.P., Ed.M.
- Health Education Specialist
- The National Center for Prevention Services (HIV)
- The Centers for Disease Control
- Atlanta, Georgia

- Davene McCarthy White, R.N., N.N.P.
- Clinical Instructor
- Howard University Hospital
- Department of Pediatrics and Child Health
- Washington, D.C.

- Lester N. Wright, M.D., M.P.H.
- Chairman, Associate Professor
- Department of Health Administration
- School of Public Health
- Loma Linda University
- Loma Linda, California